# 5. List of References

* Cited in text

Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. Goldfrank's toxicologic emergencies. Stamford, CT: Appleton & Lange, 1429–1449.
*Allran JW, Karasov WH. 2000. Effects of atrazine and nitrate on northern leopard frog (Rana pipiens) larvae exposed in the laboratory from posthatch through metamorphosis. Environ Toxicol Chem 19(11):2850–2855.
*Anderson TD, Lydy MJ. 2002. Increased toxicity to invertebrates associated with a mixture of atrazine and organophosphate insecticides. Environ Toxicol Chem 21:1507–1514.12109753
Arbuckle TE, Lin Z, Mery LS. 2001. An exploratory analysis of the effect of pesticide exposure on the risk of spontaneous abortion in an Ontario farm population. Environ Health Perspect 109(8):851–857.11564623
*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry.
*ATSDR. 1996. Toxicological profile for diazinon. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Draft for public comment. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service. http://www.atsdr.cdc.gov/iphome.html.
*ATSDR. 2001b. Guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2003. Toxicological profile for atrazine. Post-public comment draft (version 1). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Avery AA. 1999. Infantile methemoglobinemia: Reexamining the role of drinking water nitrates. Environ Health Perspect 107(7):583–586.10379005
Baumeister M. 1982. Experimental models for the biological determination of N-nitroso compounds formed from amines and nitrite. Toxicol Lett 12:281–288.6753243
Belden JB, Lydy MJ. 2000. Impact of atrazine on organophosphate insecticide toxicity. Environ Toxicol Chem 19(9):2266–2274.
*Bontoyan WR, Law MW, Wright DP. 1979. Nitrosamines in agricultural and home-use pesticides. J Agric Food Chem 27:631–635.447935
Bosch HM, Rosefield AB, Huston R, 1950. Methemoglobinemia and Minnesota well supplies. J Am Water Works Assoc 42:161–170.
Cocco P, Ward MH, Buiatti E. 1996. Occupational risk factors for gastric cancer: An overview. Epidemiol Rev 18(2):218–234.9021314
Cohen DB. 1986. Ground water contamination by toxic substances; A California assessment. In: Garner WY, Honeycutt RC, Nigg HN, eds. Evaluation of pesticides in ground water. Washington, DC: American Chemical Society, 499–529.
Cohen S, Svrjcek A, Durborow T, 1999. Water quality impacts by golf courses. J Environ Qual 28(3):798–809.
Cohen SZ, Nickerson S, Maxey R, 1990. A ground water monitoring study for pesticides and nitrates associated with golf courses on Cape Cod Massachusetts USA. Ground Water Monit Rev 10(1):160–173.
Cooper RL, Stoker TE, Tyrey L, 2000. Atrazine disrupts the hypothalamic control of pituitary-ovarian function. Toxicol Sci 53:297–307.10696778
Cova D, Molinari GP, Rossini L. 1990. Focus on toxicological aspects of pesticide chemical interaction in drinking water contamination. Ecotoxicol Environ Saf 20:234–240.2090439
*Cova D, Nebuloni C, Arnoldi A, 1996. N-nitrosation of triazines in human gastric juice. J Agric Food Chem 44:2852–2855.
Curtis KM, Savitz DA, Weinberg CR, 1999. The effect of pesticide exposure on time to pregnancy. Epidemiology 10:112–117.10069244
*Dmitrenko NP, Bardik YV, Krivenchuk VE, 1996. [Study of simazine nitrosation in rats]. Dopov Nats Akad Nauk Ukr 0(1):93–95. (Russian)
Donna A, Crosignani P, Robutti F, 1989. Triazine herbicides and ovarian epithelial neoplasms. Scand J Work Environ Health 15:47–53.
Dressel TD, Goodale RL, Borner JW, 1980. A study of the cholinesterases of the canine pancreatic sphincters and the relationship between reduced butyrylcholinesterase activity and pancreatic ductal hypertension. Ann Surg 192(5):614–619.7436591
Dunkelberg H, Fuchs J, Hengstler JG, 1994. Genotoxic effects of the herbicides alachlor, atrazine, pendimethaline, and simazine in mammalian cells. Bull Environ Contam Toxicol 52:498–504.8167442
*Eisenbeis SJ, Lynch DL, Hampel AE. 1981. The Ames mutagen assay tested against herbicides and herbicide combinations. Soil Sci 131(1):44–47.
Eisenbrand G, Ivankovic S, Preussmann R, 1975a. Some recent results on the chemistry, formation, and biological activity of N-nitroso compounds. Gann Monogr Cancer Res 17:133–143.
*Eisenbrand G, Ungerer O, Preussmann R. 1975b. Formation of N-nitroso compounds from agricultural chemicals and nitrite. In: Bogovski P, Walker EA, Davis W, eds. N-nitroso compounds in the environment. Switzerland: International Agency for Research on Cancer, 71–74.
Eisenbrand G, Ungerer O, Preussmann R. 1975c. The reaction of nitrite with pesticides. II. Formation, chemical properties and carcinogenic activity of the N-nitroso derivative of N-methyl-1-naphthyl carbamate (carbaryl). Food Cosmet Toxicol 13:365–367.239889
Elespuru RK, Lijinsky W. 1973. The formation of carcinogenic nitroso compounds from nitrite and some types of agricultural chemicals. Food Cosmet Toxicol 11:807–817.4203521
EPA. 1990. Criteria document for nitrate/nitrite. Washington, DC: Office of Drinking Water, U.S. Environmental Protection Agency.
*EPA. 2000. Human health risk assessment: Diazinon: Memorandum attached. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppsrrd1/op/diazinon.htm.
*EPA. 2002a. Memorandum: Atrazine/DACT- fourth report of the hazard identification assessment review committee. Document attached. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppsrrd1/reregistration/atrazine/hed_hiarc_atrazine_5april02.PDF.
*EPA. 2002b. Revised human health risk assessment: Atrazine. Memorandum attached. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppsrrd1/reregistration/atrazine/hed_redchap_16apr02.PDF.
*EPA. 2002c. The grouping of a series of triazine pesticides based on a common mechanism of toxicity. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticides Programs. http://www.epa.gov/oppsrrd1/cumulative/triazines/triazinescommonmech.pdf.
EPA. 2003. Pesticides. Regulating pesticides. The Food Quality Protection Act (FQPA). http://www.epa.gov/oppfead1/fqpa/backgrnd.htm.
Fabrizi L, Gemma S, Testai E, 1999. Identification of the cytochrome P450 isoenzymes involved in the metabolism of diazinon in the rat liver. J Biochem Mol Toxicol 13(1):53–61.9890448
*Faust M, Altenburger R, Boedeker W, 1993. Additive effects of herbicide combinations on aquatic non-target organisms. Sci Total Environ 0:941–952.
Fernandez M, ĽHaridon JL, Gauthier L, 1993. Amphibian micronucleus test(s): a simple and reliable method for evaluating in vivo genotoxic effects of freshwater pollutants and radiations. Initial assessment. Mutat Res 292:83–99.7688100
*Fine DH, Roundbehler DP, Belcher, 1976. N-nitroso compounds in air and water. In: Environmental N-nitroso compounds analysis and formation: proceedings of a working conference held at the Polytechnical Institute, Tallinn, Estonian SSR, 1–3. WHO: Lyon, France. IARC Sci Publ 14:401–408.
Fishbein L. 1978. Overview of potential mutagenic problems posed by some pesticides and their trace impurities. Environ Health Perspect 27:125–131.367764
Fishbein L. 1979. Overview of some aspects of occurrence, formation and analysis of nitrosamines. Sci Total Environ 13:157–175.386508
Frick TW, Dalo S, OĽeary JF, 1987. Effects of insecticide, diazinon, on pancreas of dog, cat and guinea pig. J Environ Pathol Toxicol Oncol 7(4):1–11.
Gilliom RJ, Barbash JE, Kolpin DW, 1999. Testing water quality for pesticide pollution: U.S. Geological Survey investigations reveal widespread contamination of the nation's water resources. Environ Sci Technol 33(7):164A–169A.
Guddewar MB, Dauterman WC. 1979. Studies on glutathione S-transferase preparation from mouse liver which conjugates chloro-s-triazine herbicides. Pestic Biochem Physiol 12(1):1–9.
*Hakura A, Suzuki S, Sawada S, 2003. Use of human liver S9 in the Ames test: Assay of three procarcinogens using human S9 derived from multiple donors. Regul Toxicol Pharmacol 37:20–27.12662906
Hanioka N, Jinno H, Tanaka-Kagawa T, 1999. In vitro metabolism of chlorotriazines: Characterization of simazine, atrazine, and propazine metabolism using liver microsomes for rats treated with various cytochrome P450 inducers. Toxicol Appl Pharmacol 156:195–205.10222312
Helma C, Eckl P, Gottmann E, 1998. Genotoxic and ecotoxic effects of groundwaters and their relation to routinely measured chemical parameters. Environ Sci Technol 32(12):1799–1805.
Hendriks AJ, Stouten MD A. 1993. Monitoring the response of microcontaminants by dynamics Daphnia magna and Leuciscus idus assays in the Rhine delta: Biological early warning as a useful supplement. Ecotoxicol Environ Saf 26:265–279.7507817
IARC. 1999a. Atrazine. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 73:59–113.10804952
IARC. 1999b. Simazine. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 73:625–640.10804969
IARC. 2003. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 885 agents, mixtures and exposures). International Agency for Research on Cancer. http://193.51.164.11/moneeval/crthall.html.
Inui H, Shiota N, Motoi Y, 2001. Metabolism of herbicides and other chemicals in human cytochrome P450 species and in transgenic potato plants co-expressing human CYP1A1, CYP2B6 and CYP2C19. J Pestic Sci 26:28–40.
*IRIS. 2003. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris.
*Ishidate M. 1983. Application of chromosomal aberration tests in vitro to the primary screening for chemicals with carcinogenic and/or genetic hazards. In: Garattini S, ed. Tests courts de cancérogénèse: Quo vadis? Montpellier: Centre de Recherches Clin Midy, 57–79.
*Ishidate M, Sofuni T, Yoshikawa K. 1981. Chromosomal aberration tests in vitro as a primary screening tool for environmental mutagens and/or carcinogens. GANN Monogr Cancer Res 27:95–108.
Janzowski C, Klein R, Preussmann R. 1980. Formation of N-Nitroso compounds of the pesticides atrazine, simazine, and carbaryl with nitrogen oxides. IARC Sci Publ 31:329–39.
Johnson CJ, Kross BC. 1990. Continuing importance of nitrate contamination of groundwater and wells in rural areas. Am J Ind Med 18:449–456.2248249
*Kearney PC. 1980. Nitrosamines and pesticides: a special report on the occurrence of nitrosamines as terminal residues resulting from agricultural use of certain pesticides. Pure Appl Chem 52:499–526.
Kearney PC, Oliver JE, Helling CS, 1977. Distribution, movement, persistence, and metabolism of N-nitrosoatrazine in soils and a model aquatic ecosystem. J Agric Food Chem 25:1177–1181.893846
Keith LH. 1976. Recent advances in the identification and analysis of organic pollutants in water. Life Sci 19:1631–1636.794607
Kettles MA, Browning SR, Prince TS, 1997. Triazine herbicide exposure and breast cancer incidence: An ecologic study of Kentucky counties. Environ Health Perspect 105(11):1222–1227.9370519
*Krull IS, Mills K, Hoffman G, 1980. The analysis of N-nitrosoatrazine and N-nitrosocarbaryl in whole mice. J Anal Toxicol 4(5):260–262.6777604
Lefkowitz RJ, Hoffman BB, Taylor P. 1996. Neurotransmission: The autonomic and somatic motor nervous systems. In: Goodman LS, Gilman A, Hardman JG, , eds., Goodman & Gilman's the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 105–139.
Lehotay SJ, Harman-Fethco JA, McConnell LL. 1998. Agricultural pesticide residues in oysters and water from two Chesapeake Bay Tributaries. Mar Pollut Bull 37(1–2):32–44.
Leoni V, D'Alessandro De Luca E, Belisario MA, 1982. On the N-nitroso derivatives of three pesticides (atrazine, carbaryl and chlorobromuron) used in agriculture. Ig Mod 78:301–320.
*L'Haridon JL, Fernandez M, Ferrier V, 1993. Evaluation of the genotoxicity of N-nitrosoatrazine, N-nitrosodiethanolamine and their precursors in vivo using the newt micronucleus test. Water Res 27(5):855–862.
*Lijinsky W. 2001. N-nitroso compounds. In: Ingham E, Cohrssen B, Powell CH, eds. Patty's Toxicology. New York, NY: John Wiley & Sons Inc., 633–681.
Lijinsky W, Epstein SS. 1970. Nitrosamines as environmental carcinogens. Nature 225:21–23.5409687
*Meisner LF, Roloff BD, Belluck DA. 1993. In vitro effects of N-nitrosoatrazine on chromosome breakage. Arch Environ Contam Toxicol 24:108–112.8466288
*Meli G, Bagnati R, Fanelli R, 1992. Metabolic profile of atrazine and N-Nitrosoatrazine in rat urine. Bull Environ Contam Toxicol 48:701–708.1504516
Meulenberg EP. 2002. A new test to identify endocrine disruptors using sex hormone-binding globulins from human serum. Eur J Lipid Sci Tech 104(2):131–136.
Mills PK. 1998. Correlation analysis of pesticide use data and cancer incidence rates in California Counties. Arch Environ Health 53(6):410–413.9886160
Mirvish SS. 1975. Formation of N-nitroso compounds: Chemistry, kinetics, and in vivo occurrence. Toxicol Appl Pharmacol 31:325–351.238307
*Mirvish SS, Gannett P, Babcook DM, 1991. N-nitrosoatrazine: synthesis, kinetics of formation, and NMR spectra and other properties. J Agric Food Chem 39(7):1205–1210.
*Moore A, Lower N. 2001. The impact of two pesticides on olfactory-mediated endocrine function in mature male Atlantic salmon (Salmo salar L.) parr. Comp Biochem Physiol B 129:269–276.11399459
Munger R, Isacson P, Hu S, 1997. Intrauterine growth retardation in Iowa communities with herbicide-contaminated drinking water supplies. Environ Health Perspect 105(3):308–314.9171992
NRC. 1995. Nitrate and nitrate in drinking water. National Research Council. Washington, DC: National Academy Press. PB95267092.
NTP. 2003. 10th report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Parkinson A. 1996. Biotransformation of xenobiotics. In: Klassen CD, ed. Casarett and Doull's toxicology: The basic science of poisons. New York: McGraw-Hill, 115–118, 145–146.
Parks NJ, Krohn KA, Mathis CA, 1981. Nitrogen-13-labeled nitrite and nitrate: Distribution and metabolism after intratracheal administration. Science 212:58–61. (As cited in EPA 1990.)7209517
Porter WP, Jaeger JW, Carlson IH. 1999. Endocrine, immune, and behavioral effects of aldicarb (carbamate), atrazine (triazine) and nitrate (fertilizers) mixtures at groundwater concentrations. Toxicol Ind Health 15(1–2):133–150.10188196
*Preussmann R, Stewart BW. 1984. N-nitroso carcinogens. ACS Monogr 182:643–828.
Quackenboss JJ, Pellizzari ED, Shubat P, 2000. Design strategy for assessing multi-pathway exposure for children: the Minnesota Children's Pesticide Exposure Study (MNCPES). J Expo Anal Environ Epidemiol 10:145–158.10791596
Ritter WF. 1990. Pesticide contamination of ground water in the United States-A review. J Environ Sci Health B B 25(1):1–29.
Savitz DA, Arbuckle T, Kaczor D, 1997. Male pesticide exposure and pregnancy outcome. Am J Epidemiol 146(12):1025–1036.9420527
*Seiler JP. 1977. Inhibition of testicular DNA synthesis by chemical mutagens and carcinogens. Preliminary results in the validation of a novel short term test. Mutat Res 46:305–310.895760
Snedeker SM, Clark H. 1998. Critical evaluation of simazine's breast cancer risk. Cornell University. Program on Breast Cancer and Environmental Risk Factors in New York State (BCERF). http://www.cfe.cornell.edu/bcerf/.
*Squillace PJ, Scott JC, Moran MJ, 2002. VOCs, pesticides, nitrate, and their mixtures in groundwater used for drinking water in the United States. Environ Sci Technol 36:1923–1930.12026972
Taets C. 1996. The effects of herbicide interaction on Chinese Hamster ovary cells. J Nat Resour Life Sci Educ 25(1):81–84.
*Taets C, Aref S, Rayburn AL. 1998. The clastogenic potential of triazine herbicide combinations found in potable water supplies. Environ Health Perspect 106(4):197–201.9487108
Taylor P. 1996. Anticholinesterase agents. In: Goodman LS, Gilman A, Hardman JG, , eds. Goodman & Gilman's the pharmacological basis of therapeutics. New York, NY: McGraw-Hill, Health Professions Division, 161–176.
Timchalk C, Dryzga MD, Langvardt PW, 1990. Determination of the effect of tridiphane on the pharmacokinetics of [^14^C]-atrazine following oral administration to male Fischer 344 rats. Toxicology 61:27–40.2315949
*Van Leeuwen JA, Waltner-Toews D, Abernathy T, 1999. Associations between stomach cancer incidence and drinking water contamination. Int J Epidemiol 28(5):836–840.10597979
*Walters CL, Carr FP A, Dyke CS, 1979. Nitrite sources and nitrosamine formation in vitro and in vivo. Food Cosmet Toxicol 17:473–479.520980
Walton G. 1951. Survey of literature relating to infant methemoglobinemia due to nitrate-contaminated water. Am J Public Health 41:986–996.
Weisenburger DD. 1990. Environmental epidemiology of non-Hodgkin's lymphoma in Eastern Nebraska. Am J Ind Med 18:303–305.2220835
Weisenburger DD, Hickman TJ, Patil KD, 1990. Carcinogenesis tests of atrazine and N-nitrosoatrazine-compounds of special interest to the Midwest. Proc Am Assoc Cancer Res 31:102.
Weisenburger DD, Joshi SS, Hickman TI, 1987. N-nitrosoatrazine (NNAT). Synthesis, chemical properties, acute toxicity, and mutagenicity. Proc Am Assoc Cancer Res 28:103.
Weisenburger DD, Joshi SS, Hickman TI, 1988. Mutagenesis tests of atrazine and N-nitrosoatrazine compounds of special interest to the midwest. Proc Am Assoc Cancer Res 29(0):106.
WHO. 1978. Environmental Health Criteria 5: Nitrates, nitrites and N-nitroso compounds. Geneva: World Health Organization.
WHO. 1998. Environmental health criteria 198: Diazinon. World Health Organization. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc198.htm.
Witter JP, Gatley SJ, Balish E. 1979. Distribution of nitrogen-13 from labeled nitrate (^13^NO_3_^−^) in humans and rats. Science 204:411–413. (As cited in EPA 1990.)441728
*Wolfe NL, Zepp RG, Gordon JA, 1976. N-nitrosamine formation from atrazine. Bull Environ Contam Toxicol 15(3):342–347.
Zeman CL, Kross B, Vlad M. 2002. A nested case-control study of methemoglobinemia risk factors in children of Transylvania, Romania. Environ Health Perspect 110(8):817–822.12153765