# SUMMARY

Atrazine, deethylatrazine, simazine, diazinon, and nitrate were chosen as the subject mixture for this interaction profile because they frequently occur together in rural well water. Atrazine and simazine are triazine herbicides, deethylatrazine is a metabolite and an environmental degradation product of atrazine and other triazine herbicides, diazinon is an organophosphorus insecticide, and nitrate is a common contaminant resulting from fertilizers and human and animal waste. The exposures of greatest concern for this mixture in rural well water are intermediate and chronic oral exposures. No pertinent health effects data or physiologically-based pharmacokinetic (PBPK) models were located for the complete mixture. Therefore, the exposure-based screening assessment of potential health hazards for this mixture depends on an evaluation of the health effects and mechanistic data for the individual components and on the joint toxic action and mechanistic data for various combinations of the components. This profile discusses and evaluates the evidence for joint toxic action among atrazine, deethylatrazine, simazine, diazinon, and nitrate. The profile also discusses how public health assessments can incorporate concerns about interactions, additivity, and potential human exposures to mixtures of these chemicals.

Effects of concern for this mixture include reproductive effects (atrazine, deethylatrazine, and simazine), neurological effects (diazinon), and hematological effects (nitrate). Although none of the components has been classified as a carcinogen, atrazine and simazine can react with nitrite (nitrate metabolite) in the environment and in vivo to form N-nitrosoatrazine and N-nitrososimazine. Structure-activity considerations raise a concern for potential carcinogenicity of these nitrosamines. However, the issue of atrazine/nitrate and simazine/nitrate combinations and potential cancer risk in humans is still unresolved and further research is needed.

To screen the mixture of atrazine, deethylatrazine, simazine, diazinon, and nitrate for potential hazards to public health, the hazard quotients (ratios of exposures to health guidance values) are estimated for the individual components. If only one or if none of the components has a hazard quotient that is at least 0.1, no further assessment of the joint toxic action is needed because additivity and/or interactions are unlikely to result in significant health hazard. If the hazard quotients for two or more of the mixture components equal or exceed 0.1, the following procedures are recommended. To screen this mixture for potential reproductive health hazard, an endpoint-specific hazard index for reproductive effects should be estimated for atrazine, deethylatrazine, and simazine (the triazine components of the mixture). The weight-of-evidence (WOE) analysis for interactions among these components indicates high confidence in the additivity assumption that is the basis for the hazard index. The potential effect of diazinon and nitrate on the reproductive toxicity of these triazines is uncertain. Separate hazard quotients are recommended to screen for the neurotoxicity of diazinon and the hematological toxicity of nitrate. The WOE analysis indicates that because the triazine components may potentiate the neurologic toxicity of diazinon, the hazard quotient for diazinon may tend to underestimate the hazard of exposure to diazinon when these triazine components are present. Confidence in these predictions is medium. No information regarding the impact of interactions on the hematological toxicity of nitrate was available, so uncertainty regarding the impact of the other components on this effect of nitrate is high.

If the reproductive hazard index for the triazines or the hazard quotient for nitrate is greater than 1, or if the hazard quotient for diazinon is close to or above 1, then further evaluation is needed (ATSDR 2001a), using biomedical judgment and community-specific health outcome data.