# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Dale Hattis, Ph. D.
  The George Perkins Marsh Institute
  Center for Toxicology, Environment, and Development
  Clark University
  Worcester, MA
- Kannan Krishnan, Ph. D.
  Department of Environmental and Occupational Health
  Faculty of Medicine
  University of Montreal, Montreal, QC, Canada
- Sheldon Wagner, M.D.
  Department of Environmental and Molecular Toxicology
  Oregon State University
  Corvallis, OR

All reviewers were selected in conformity with the conditions for peer review specified in CERCLA Section 104(I)(13).

Scientists from ATSDR have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.