# Appendix C Background Information for Diazinon

Diazinon is an organophosphorus insecticide. The structure of diazinon and its toxic metabolite, diazoxon, are provided in Appendix E.

## C.1 Toxicokinetics

Diazinon is rapidly absorbed from the gastrointestinal tract, based on case reports of ingestion of diazinon formulation or solution, on single oral dose studies in rats and dogs, and on repeated oral dose studies in rats. Absorption in rats and dogs was at least 85% of the dose (ATSDR 1996; WHO 1998). The main features of diazinon metabolism are:

- activation of diazinon through conversion of the P=S moiety to P=O, resulting in the toxic intermediate, diazoxon;
- cleavage of the ester bonds of diazinon and diazoxon resulting in 2-isopropyl-4-methyl-6-hydropyrimidine (from both), diethylphosphorothioc acid (from diazinon), and diethylphosphoric acid (from diazoxon);
- oxidation of the isopropyl substituent of 2-isopropyl-4-methyl-6-hydropyrimidine to the corresponding primary and tertiary alcohols;
- glutathione-mediated cleavage of the ester bond with the formation of a glutathione conjugate (minor pathway).

The resulting metabolites are excreted primarily in the urine (ATSDR 1996; WHO 1998).

The metabolic activation of diazinon to diazoxon is carried out by microsomal cytochrome P450 monooxygenases. A single study of diazinon in rat hepatic microsomes has reported that CYP2B1/2 are the major P450 isozymes that catalyze the production of diazoxon (Fabrizi et al. 1999).

## C.2 Health Effects

The principal toxic effect of diazinon in humans, experimental animals, and insects is acetylcholinesterase inhibition. Acetylcholine is a neurotransmitter in the central and peripheral neurons. Inhibition of acetylcholinesterase, the enzyme that breaks down and terminates the action of acetylcholine, results in the accumulation of acetylcholine at acetylcholine receptors leading to continued stimulation.

In humans and experimental animals, the accumulation of acetylcholine results in cholinergic responses in the peripheral (muscarinic and nicotinic) and central nervous system and neuromuscular junctions. These cholinergic responses, seen in severe acetylcholinesterase inhibition, include excessive glandular secretions (salivation, lacrimation, rhinitis), miosis, bronchoconstriction, vasodilation, hypotension, diarrhea, nausea, vomiting, urinary incontinence, and bradycardia associated with muscarinic receptor stimulation. Tachycardia, mydriasis (dilation of the pupil), muscle fasciculations, cramping, twitching, muscle weakness, muscle paralysis, and hypertension are associated with nicotinic receptor stimulation. Central nervous system toxicity includes respiratory depression, anxiety, insomnia, headache, apathy, drowsiness, dizziness, loss of concentration, confusion, tremors, convulsions, and coma. These effects usually appear within a few minutes to 24 hours after exposure, depending on the extent and route of exposure. In nonfatal exposures, the effects are usually transient, with rapid and complete recovery following cessation of exposure. Recovery from diazinon poisoning results from increased availability of active acetylcholinesterase either from synthesis of new enzyme, the spontaneous hydrolysis of the enzyme-phosphate ester complex, or treatment with atropine, a competitive antagonist of acetylcholine at muscarinic and central nervous system receptors, and with pralidoxime (2-PAM), a drug that regenerates inhibited acetylcholinesterase enzyme by displacing the diethylphosphoester bond that diazoxon forms at the active site (Aaron and Howland 1998; ATSDR 1996).

In some cases, however, diazinon may cause a condition known as the intermediate syndrome (Aaron and Howland 1998; WHO 1998). This syndrome occurs during apparent recovery about 24–96 hours after severe cholinergic crisis, and includes paralysis of the respiratory muscles, upper extremity muscles, neck flexors, and motor cranial nerves. Diazinon has been tested for organophosphate-induced delayed neurotoxicity in chickens; results were negative (ATSDR 1996). No cases of delayed neuropathy from diazinon exposure have been reported (ATSDR 1996; WHO 1998).

Acetylcholinesterase activity is also present in erythrocytes where it is known as erythrocyte acetylcholinesterase. Both forms of acetylcholinesterase are produced by the same gene and are kinetically identical. In in vitro assays, erythrocyte and neural acetylcholinesterase are inhibited to roughly the same extent by exposure to diazinon and many other organophosphorus compounds with insecticidal activity; measurement of erythrocyte acetylcholinesterase can be used as a surrogate indicator of the extent of inhibition of neural acetylcholinesterase (ATSDR 1996).

A cholinesterase capable of hydrolyzing acetylcholine and butyrlcholine is produced by the liver and circulates in the blood. This enzyme, referred to as serum cholinesterase, plasma cholinesterase, pseudocholinesterase, or butyrylcholinesterase, is also inhibited by diazinon and is often used as a marker for exposure (ATSDR 1996). This enzyme is present in some nonneural cells in the central and peripheral nervous systems as well as in plasma and serum, the liver, and other organs. Its physiologic function is not known, but is hypothesized to be the hydrolysis of esters ingested from plants (Lefkowitz et al. 1996). Plasma cholinesterases are also inhibited by organophosphate compounds through irreversible binding; this binding can act as a detoxification mechanism as it affords some protection to acetylcholinesterase in the nervous system (Parkinson 1996; Taylor 1996). In general, this enzyme is inhibited by diazinon at lower levels of exposure than required to inhibit neural or erythrocyte acetylcholinesterase (ATSDR 1996).

A few case reports of diazinon ingestion or dermal exposure have reported acute pancreatitis as a component of severe diazinon intoxication (ATSDR 1996; WHO 1998). Diazinon at sublethal doses also caused pancreatic ductal hypertension in dogs, and acute pancreatitis in dogs and guinea pigs but not in cats (Dressel et al. 1980; Frick et al. 1987). Effects on the pancreas appear to be a high-dose phenomenon.

Epidemiological studies provide no specific evidence of carcinogenicity for diazinon, and the available animal studies do not suggest that diazinon would be likely to cause cancer in humans (ATSDR 1996; EPA 2000).

## C.3 Mechanisms of Action

Diazinon and diazoxon inhibit acetylcholinesterase by reacting with the active site to form a stable dialkylphosphorylated enzyme that cannot hydrolyze acetylcholine. Diazoxon, the active metabolic intermediate of diazinon, is much more potent than diazinon in inhibiting acetylcholinesterase (ATSDR 1996; WHO 1998).

The mechanism of action with regard to pancreatic toxicity in dogs and guinea pigs appears to be inhibition of butyrylcholinesterase in the pancreas and its smooth muscle sphincters, leading to ductal hypertension and cholinergic hyperstimulation of the acinar cells (Dressel et al. 1980; Frick et al. 1987).

## C.4 Health Guidelines

ATSDR (1996) derived an intermediate inhalation MRL of 0.009 mg/m^3^ for brain acetylcholinesterase inhibition diazinon based on a NOAEL of 0.46 mg/m^3^ in a 21-day study in rats. An uncertainty factor of 30 was applied. The LOAEL (20% decrease in brain acetylcholinesterase) was 1.57 mg/m^3^.

ATSDR (1996) derived an intermediate oral MRL of 0.0002 mg/kg/day based on a NOAEL of 0.021 mg/kg/day for brain acetylcholinesterase inhibition in dogs given diazinon in their food daily for 13 weeks. An uncertainty factor of 100 was used. The LOAEL (31% decrease in erythrocyte and brain acetylcholinesterase) was 5.9 mg/kg/day. A chronic oral MRL was not derived because the chronic NOAEL (0.05 mg/kg/day for brain cholinesterase inhibition in rats) that was considered as the basis for the MRL would have resulted in an MRL (0.0005 mg/kg/day) that was slightly higher than the intermediate oral MRL. Since the intermediate-duration MRL would be more protective, it was the only one derived, and was considered protective for individuals living near hazardous waste sites.

EPA (IRIS 2003) does not have an online file for diazinon.

The EPA (2000) Office of Pesticide Programs derived acute and chronic RfDs of 0.0025 and 0.0002 mg/kg/day based on NOAELs for cholinesterase inhibition of 2.5 mg/kg/day (in rats) and 0.02 mg/kg/day in seven feeding studies (in rats and dogs), respectively. An additional 10-fold FQPA safety factor (EPA 2003) was not used for special sensitivity in infants and children because the EPA concluded that the data indicated that this factor could be reduced to 1-fold. The PADs are therefore the same as the RfDs. Although this RfD and PAD are not on IRIS, they have been subjected to extensive review, including public comment, and are available online (EPA 2000).

NTP (2003) and IARC (2003) do not include diazinon in their listings. The EPA (2000) Office of Pesticide Programs classified diazinon as a not likely human carcinogen based on the lack of evidence of carcinogenicity in mice and rats.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The intermediate oral MRL of 0.0002 mg/kg/day for neurological effects (brain acetylcholinesterase inhibition in dogs for 13-week oral exposure) is appropriate for use as a chronic guidance value as well (ATSDR 1996), and is the same as the chronic oral RfD developed by EPA (2000). An uncertainty factor of 100 was applied to a NOAEL of 0.021 mg/kg/day, as described in the previous section. The LOAEL (31% decrease in erythrocyte and brain acetylcholinesterase) was 5.9 mg/kg/day.

### Summary (TTD for Diazinon)

MRL_NEURO_ =0.0002 mg/kg/day

## C.6 References

Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. Goldfrank's toxicologic emergencies. Stamford, CT: Appleton & Lange, 1429–1449.
ATSDR. 1996. Toxicological profile for diazinon. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Dressel TD, Goodale RL, Borner JW, 1980. A study of the cholinesterases of the canine pancreatic sphincters and the relationship between reduced butyrylcholinesterase activity and pancreatic ductal hypertension. Ann Surg 192(5):614–619.7436591
EPA. 2000. Human health risk assessment: Diazinon: Memorandum attached. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/pesticides/op/diazinon/final_red.pdf.
EPA. 2003. Pesticides. Regulating pesticides. The Food Quality Protection Act (FQPA). http://www.epa.gov/oppfead1/fqpa/backgrnd.htm.
Fabrizi L, Gemma S, Testai E, 1999. Identification of the cytochrome P450 isoenzymes involved in the metabolism of diazinon in the rat liver. J Biochem Mol Toxicol 13(1):53–61.9890448
Frick TW, Dalo S, OĽeary JF, 1987. Effects of insecticide, diazinon, on pancreas of dog, cat and guinea pig. J Environ Pathol Toxicol Oncol 7(4):1–11.
IARC. 2003. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 885 agents, mixtures and exposures). International Agency for Research on Cancer. http://193.51.164.11/moneeval/crthall.html.
IRIS. 2003. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris.
Lefkowitz RJ, Hoffman BB, Taylor P. 1996. Neurotransmission: The autonomic and somatic motor nervous systems. In: Goodman LS, Gilman A, Hardman JG, , eds., Goodman & Gilman's the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 105–139.
NTP. 2003. 10th report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Parkinson A. 1996. Biotransformation of xenobiotics. In: Klassen CD, ed. Casarett and Doull's Toxicology: The basic science of poisons. New York: McGraw-Hill, 115–118, 145–146.
Taylor P. 1996. Anticholinesterase agents. In: Goodman LS, Gilman A, Hardman JG, , eds. Goodman & Gilman's the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 161–176.
WHO. 1998. Environmental health criteria 198: Diazinon. World Health Organization. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc198.htm.