# Appendix B Background Information for Simazine

Simazine is a triazine herbicide (an herbicide containing the s-triazine ring) that inhibits photosynthesis in plants. The structure of simazine is depicted in Appendix E, and also in the metabolic scheme presented previously in Figure 2.

## B.1 Toxicokinetics

Less information is available regarding the toxicokinetics of simazine than was available for atrazine. The percent of administered radiolabel excreted in urine during 96 hours after oral dosing of rats with radiolabeled simazine was 49.3%, indicating that absorption was at least 49.3% (EPA 2002c).

In experimental animals, simazine is metabolized by (EPA 2002c; Guddewar and Dauterman 1979; IARC 1999b):

- successive N-dealkylation to deisopropylatrazine (desisopropyl atrazine), and didealkylatrazine (commonly called diaminochlorotriazine or DACT);
- glutathione conjugation of simazine and the above-listed metabolites (probably followed by conversion to mercapturic acid derivatives).

Deisopropylatrazine and diaminochlorotriazine also are metabolites of atrazine. Figure 2 summarizes the metabolic dealkylation pathways that are common to atrazine and simazine

The dealkylation of simazine is carried out by microsomal cytochrome P450 enzymes (EPA 2002c). Studies with rat liver microsomes indicate that the specific isozymes involved in this dealkylation are CYP1A1/2 (Hanioka et al. 1999).

An oral study with radiolabeled simazine in rats indicates extensive tissue distribution of radioactivity, including to the brain (EPA 2002c).

## B.2 Health Effects

Some of the epidemiological studies reviewed in Appendix A were on agricultural exposure to trazines in Midwestern states, and did not specify whether exposure to simazine occurred. Because atrazine and cyanazine are the main triazines used as herbicides in the corn belt of the Midwest, it is likely that exposures were mainly to atrazine and cyanazine (Snedeker and Clark 1998). The Ontario farm survey studies reviewed in Appendix A listed atrazine and cyanazine, but not simazine. IARC (1999b) stated that no human reproductive and developmental effects data were available for simazine, and no human cancer data were available for simazine alone.

Studies in rats indicate that simazine has effects on reproductive function and reproductive development similar to those of atrazine, as do its metabolites deisopropylatrazine and diaminochlorotriazine (EPA 2002c). Also, simazine and diaminochlorotriazine cause mammary gland tumors in Sprague-Dawley female rats (EPA 2002c). As explained previously for atrazine, this carcinogenic effect of simazine is not considered relevant to humans (see Section A.2 and A.3).

## B.3 Mechanisms of Action

The mechanism of action of simazine and its metabolites deisopropylatrazine and diaminochlorotriazine is considered to be the same as for atrazine as described in Section A.3 with regard to neuroendocrine, reproductive, and carcinogenic effects (EPA 2002c).

## B.4 Health Guidelines

ATSDR has not developed a toxicological profile or MRLs for simazine.

EPA derived an oral RfD of 0.005 mg/kg/day based on a NOAEL of 0.52 mg/kg/day in a chronic dietary study in rats, and using an uncertainty factor of 100 (IRIS 2003). The LOAEL was 5.3 mg/kg/day. The critical effects were reduction in weight gain and hematological changes (mainly depression of red cell parameters. This RfD was verified by EPA in 1993; significant new studies have been published since that time (IRIS 2003).

More recently than the 1993 assessment that is on IRIS (2003), the EPA (2002c) Office of Pesticide Programs concluded that atrazine, deethylatrazine, diaminochlorotriazine, deisopropylatrazine, simazine, and propazine should be considered a Common Mechanism Group for cumulative risk assessment due to their ability to suppress the pituitary LH surge resulting in effects on reproductive function and reproductive development. These effects were considered the critical effects. Taking into account newer toxicological and mechanistic data, EPA (2002b) developed new RfDs for atrazine and its chlorinated metabolites (see Section A.4), but has not yet developed new RfDs for simazine.

NTP (2003) does not include simazine in its listings.

IARC (1999b) classified simazine as not classifiable as to its carcinogenicity to humans (Group 3) based on inadequate evidence in humans and sufficient evidence in experimental animals.

EPA has not published a cancer assessment of simazine on IRIS (2003).

## B.5 Derivation of Target Organ Toxicity Dose (TTD) Values

It is recommended that the chronic PAD of 0.0018 mg/kg/day for atrazine and its chlorinated metabolites (EPA 2002b) also be adopted as a provisional TTD for reproductive effects for simazine. The derivation of this guidance value is described in Section A.5. The structure, molecular weights, metabolism, toxicity, and mechanisms of action of these chemicals are similar, and they are considered to belong to a Common Mechanism Group for cumulative risk assessment due to their ability to suppress the pituitary LH surge resulting in effects on reproductive function and reproductive development (EPA 2002c). This value is recommended as an interim measure until an up-to-date guidance value is developed specifically for simazine.

### Summary (TTD for Simazine)

TTD_REPRO_ = 0.0018 mg/kg/day

## B.6 References

EPA. 2002b. Revised human health risk assessment: Atrazine: Memorandum attached. Washington, DC: U.S. Environmental Protection Agency. Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/oppsrrd1/reregistration/atrazine/hed_redchap_16apr02.PDF.
EPA. 2002c. The grouping of a series of triazine pesticides based on a common mechanism of toxicity. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticides Program. http://www.epa.gov/oppsrrd1/cumulative/triazines/triazinescommonmech.pdf.
Guddewar MB, Dauterman WC. 1979. Studies on glutathione S-transferase preparation from mouse liver which conjugates chloro-s-triazine herbicides. Pestic Biochem Physiol 12(1):1–9.
Hanioka N, Jinno H, Tanaka-Kagawa T, 1999. In vitro metabolism of chlorotriazines: Characterization of simazine, atrazine, and propazine metabolism using liver microsomes for rats treated with various cytochrome P450 inducers. Toxicol Appl Pharmacol 156:195–205.10222312
IARC. 1999b. Simazine. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 73:625–640.
IRIS. 2003. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris.
NTP. 2003. 10th report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Snedeker SM, Clark H. 1998. Critical evaluation of simazine's breast cancer risk. Cornell University. Program on Breast Cancer and Environmental Risk Factors in New York State (BCERF). http://www.cfe.cornell.edu/bcerf/.