# Appendix A Background Information for Atrazine and Deethylatrazine

Atrazine is a triazine herbicide (an herbicide containing the s-triazine ring) that inhibits photosynthesis in plants. Deethylatrazine is a metabolite and environmental degradation product of atrazine. The structures of these chemicals are depicted in Appendix E, and also in the metabolic scheme presented later in this appendix.

## A.1 Toxicokinetics

Atrazine is rapidly absorbed from the gastrointestinal tract, based on tissue distribution in case reports of atrazine ingestion and on plasma concentrations and urinary and fecal excretion in single dose studies in rats (ATSDR 2003; EPA 2002c). Absorption of atrazine, based on excretion of atrazine and its metabolites in the urine of rats during 72–96 hours after dosing, ranged from at least 37% (one study; high dose) to at least 66% (three studies; lower doses) (EPA 2002c). Fecal excretion of atrazine and metabolites accounted for 14% of the dose in 24 hours and 19% of the dose in 72 hours after dosing (Timchalk et al. 1990). Based on the fecal excretion data, at least 81% of the dose of atrazine was absorbed.

In experimental animals and humans, atrazine is metabolized by (ATSDR 2003; EPA 2002c):

- successive N-dealkylation to deethylatrazine (desethylatrazine) or deisopropylatrazine (desisopropyl atrazine), and didealkylatrazine (commonly called diaminochlorotriazine or DACT), the major urinary metabolite;
- glutathione conjugation of atrazine and the above-listed metabolites, followed by conversion to mercapturic acid derivatives (atrazine mercapturate, deethylatrazine mercapturate, and so forth);

The dealkylation of atrazine is carried out by microsomal cytochrome P450 enzymes (ATSDR 2003; EPA 2002c). Studies with human liver microsomes indicated that CYP1A2 is the primary isozyme involved in this Phase 1 metabolism (ATSDR 2003). Studies in rat liver microsomes, conducted by a different group of investigators, initially indicated that CYP2B1 and 2C11 were the primary isozymes for atrazine metabolism in the rat (ATSDR 2003), but further in vitro studies by the same group concluded that CYP1A1/w is the primary isozyme involved in the dealkylation of atrazine, and that CYP 2B1/2 may be involved in hydroxylation of the isopropyl group (Hanioka et al. 1999).

Oral studies with radiolabeled atrazine in rats indicate extensive tissue distribution of radioactivity, including to the brain (EPA 2002c).

The major route of excretion is urinary (ATSDR 2003; EPA 2002c).

Studies of the toxicokinetics of deethylatrazine do not appear to be available (ATSDR 2003; EPA 2002a, 2002b, 2002c). The metabolism of deethylatrazine can be inferred from the metabolism of atrazine. Deethylatrazine is expected to be conjugated with glutathione or further dealkylated to diaminochlorotriazine, followed by conjugation with glutathione.

Deisopropylatrazine and diaminochlorotriazine also are metabolites of simazine. Figure 2 summarizes the metabolic dealkylation pathways that are common to atrazine and simazine, and includes deethylatrazine.

## A.2 Health Effects

Based on results of studies in experimental animals, to be reviewed later in this section, concerns for the potential impacts of atrazine on human health include reproductive and carcinogenic effects. The epidemiological studies, however, provide little evidence of such impacts.

Three related survey studies of farm couples in Ontario investigated the potential impact of atrazine exposure (primarily direct exposure of the men) on reproductive and developmental endpoints including time to pregnancy, spontaneous abortion, preterm delivery, sex ratio, and small for gestational age (Arbuckle et al. 2001; Curtis et al. 1999; Savitz et al. 1997). These studies controlled for potential reproductive confounders, but relied entirely on self reporting of exposure and pregnancy outcome. The only significant reported association was an elevated odds ratio for preterm delivery with atrazine exposure through its use as an herbicide in the yard (but not with use on crops). Similar results were reported for triazine use in the yard (but not on crops) in the same study. The preterm delivery odds ratios were not adjusted for exposure to other pesticides (ATSDR 2003). A study of low birth weight, prematurity, and intrauterine growth retardation in Iowa communities with herbicide-contaminated municipal water supply reported an elevated relative risk for intrauterine growth retardation (adjusted for mother’s age) as compared with communities served by other water supplies (Munger et al. 1997). Results for low birth weight and prematurity were not significant. Multiple linear regression analyses revealed that, after controlling for potential confounding factors including maternal smoking, atrazine was more strongly correlated with intrauterine growth retardation than were the other herbicides, but the herbicides (atrazine, cyanazine, metolachlor) were intercorrelated. In addition, estimates of exposure and confounding factors were made on the community rather than individual level. Thus, these studies do not provide adequate evidence of reproductive effects in humans, but may indicate a need for further study.

Figure 2 Metabolic Pathways in Common to Atrazine and Simazine^*^ * Derived from EPA 2002c

Atrazine causes neuroendocrine, reproductive, and reproductive developmental effects in experimental animals. Animal studies have shown that atrazine disrupts estrus cyclicity (i.e., irregular ovarian cycling and changes in the number and/or percentage of days in estrus and diestrus) and alters plasma hormone levels in rats and pigs. These effects appear to be mediated by changes in the hypothalamic-pituitary-ovary axis that are species-, and even strain-, specific. In Sprague-Dawley rats, atrazine accelerates the normal process of reproductive senescence, which is initiated by a failure of the hypothalamus to release levels of gonadotropin releasing hormone (GnRH) that are adequate to stimulate the pituitary to release LH. Without sufficient LH, ovulation does not occur, estrogen levels remain high, and persistent estrus results. In other strains of rats, atrazine causes elevated progesterone levels, which leads to pseudopregnancy and persistent diestrus (ATSDR 2003).

The mechanism of reproductive senescence in humans does not involve disruption of hormonal regulation, but is initiated by depletion of ova in the ovaries, which ultimately results in decreased plasma estrogen levels. Therefore, disruption of the menstrual cycle or acceleration of reproductive senescence is not anticipated to occur in humans as a result of atrazine exposure. However, it is not known whether atrazine will cause other perturbations in the hypothalamus-pituitary-gonad axis resulting in reproductive effects in human (ATSDR 2003).

Developmental effects have been observed following pregestational, gestational, and lactational oral exposure of rat and rabbit dams and peripubertal oral exposure of rats to atrazine. The observed effects included impaired development of the reproductive system, postimplantation losses, decreases in fetal body weight, incomplete ossification, and neurodevelopmental effects (ATSDR 2003).

A number of epidemiology studies have investigated the carcinogenic potential of atrazine or triazine herbicides (ATSDR 2003; IARC 1999a). These studies include cohort studies of triazine manufacturing workers, case-control studies of farmers using atrazine or triazines, and ecological studies of populations in agricultural areas with high atrazine or triazine use and populations of areas with atrazine-contaminated drinking water. Results of these studies were inconclusive. Odds ratios, standardized mortality ratios (SMRs), or relative risks generally were not elevated or were not statistically significantly elevated after adjustment for exposure to other pesticides. A few studies reported statistically significant correlations or elevated odds ratios for cancer of the prostate (Mills 1998), breast (Kettles et al. 1997), ovary (Donna et al. 1989), or stomach (Van Leeuwen et al. 1999) and triazine or atrazine exposure. These studies, however, had no individual measures of exposure and/or no accounting for exposure to other pesticides, and are not confirmed by the other available epidemiological studies on the same chemicals.

Statistically significant earlier onset or increased incidences of mammary tumors were observed in female Sprague-Dawley rats, but not in female F344 rats or in mice (ATSDR 2003). The early onset of mammary tumors in female Sprague-Dawley rats is believed to be the result of atrazine-induced acceleration of reproductive senescence, as further explained under mechanisms of action.

Deethylatrazine was not explicitly considered in the epidemiology studies. Because it is frequently detected in surface and groundwaters that contain atrazine (Gilliom et al. 1999; Squillace et al. 2002), studies that involved exposure to atrazine or triazines through drinking water probably included exposure to deethylatrazine.

A few studies of deethylatrazine have been performed in animals. In these studies, deethylatrazine generally produced the same effects as atrazine. Diaminochlorotriazine, a metabolite of both atrazine and deethylatrazine, has been tested more extensively and caused similar reproductive function and reproductive developmental effects, and carcinogenic effects (mammary gland tumors in Sprague-Dawley female rats) affects as did atrazine (EPA 2002c). Therefore, it is reasonable to assume that deethylatrazine will do so as well.

## A.3 Mechanisms of Action

The primary target of atrazine in some animal species is the female reproductive system. Altered estrus cyclicity has been observed in Sprague-Dawley, Long-Evans, and Donryu rats following exposure to ≥5 mg/kg/day atrazine for intermediate or chronic durations and to a single dose of 300 mg/kg/day. Atrazine does not appear to have estrogenic activity. Atrazine is thought to disrupt endocrine function, and the estrus cycle, primarily through its action on the central nervous system in a manner very similar to the known mechanism of reproductive senescence in some strains of rats. In certain strains of rats, including Sprague-Dawley and Long-Evans, reproductive senescence begins by 1 year of age, and results from inadequate stimulation of the pituitary by the hypothalamus to release LH; low serum levels of LH lead to anovulation, persistent high plasma levels of estrogen, and persistent estrus. Atrazine apparently accelerates the process of reproductive senescence in these strains of rats (ATSDR 2003).

Atrazine has been shown to induce mammary tumor formation in female Sprague-Dawley rats, but not male Sprague-Dawley or male or female F344 rats. This effect is also thought to be the result of acceleration of reproductive senescence, as described above. Both the failure to ovulate and the state of persistent estrus lead to constant elevated serum levels of endogenous estrogen, which may result in tumor formation in estrogen-sensitive tissues. The rat does not appear to be an adequate model for potential atrazine carcinogenicity in women because reproductive senescence in women involves ovarian depletion and decreased serum estrogen levels instead of decreasing hypothalamic function and increased serum estrogen levels (ATSDR 2003; EPA 2002a, 2002b, 2002c).

As previously stated, atrazine has been shown to alter serum LH and prolactin levels in Sprague-Dawley rats by altering the hypothalamic control of these hormones (Cooper et al. 2000). LH and prolactin are released from the pituitary in response to GnRH from the hypothalamus. One proposed mechanism is that atrazine decreases the hypothalamic secretion of norepinephrine, which in turn decreases the release of GnRH (EPA 2002a, 2002c). Another proposed mechanism is that atrazine disrupts hypothalamic release of GnRH by interfering with the binding of some ligands, but not others, to the GABA_A_ receptors in a noncompetitive manner (ATSDR 2003).

## A.4 Health Guidelines

ATSDR (2003) did not derive inhalation MRLs for atrazine because of the lack of suitable data.

ATSDR (2003) derived an acute oral MRL of 0.01 mg/kg/day based on a no-observed-adverse-effect level (NOAEL) of 1 mg/kg/day for decreased body weight gain in rabbits administered atrazine by gavage on gestation days 7–19, and using an uncertainty factor of 100. The LOAEL was 5 mg/kg/day; slight but statistically significant reductions in food consumption and body weight gain were seen at this dose level.

ATSDR (2003) derived an intermediate oral MRL of 0.003 mg/kg/day based on a LOAEL for delayed onset of estrus in pigs using an uncertainty factor of 300.

EPA derived an oral RfD of 0.035 mg/kg/day based on a NOAEL of 3.5 mg/kg/day in a chronic dietary study in rats, and using an uncertainty factor of 100 (IRIS 2003). The LOAEL was 25 mg/kg/day. The critical effects were decreased body weight gain in the rat study and cardiac toxicity in a 1-year dietary study in dogs. This RfD was verified by EPA in 1993; significant new studies have been published since that time (IRIS 2003).

More recently, the EPA (2002b) Office of Pesticide Programs derived an acute RfD of 0.10 mg/kg/day based on a weight-of-evidence analysis of four developmental studies, and a chronic RfD of 0.018 mg/kg/day based on attenuation of the LH surge and estrus cycle disruptions in female Sprague Dawley rats. Although not on IRIS, these derivations include a consideration of toxicological and mechanistic data that have become available since the RfD on IRIS was derived. They have been subjected to extensive review, including public comment, and are available online (EPA 2002b). A FQPA default safety factor of 10 (EPA 2003) was applied to protect infants and children (and other populations) when assessing dietary (food + drinking water) exposures, resulting in a acute population adjusted dose (PAD) of 0.01 mg/kg/day and a chronic PAD of 0.0018 mg/kg/day (EPA 2002b). These RfDs and PADs are for atrazine together with its chlorinated metabolites (including deethylatrazine), which are considered to have equivalent toxicity to atrazine.

The EPA (2002c) Office of Pesticide Programs has concluded that atrazine, deethylatrazine, diaminochlorotriazine, deisopropylatrazine, simazine, and propazine should be considered a Common Mechanism Group for cumulative risk assessment due to their ability to suppress the pituitary LH surge resulting in effects on reproductive function and reproductive development.

The National Toxicology Program (NTP 2003) does not include atrazine in its listings.

The International Agency for Research on Cancer (IARC 1999a) classified atrazine as not classifiable as to its carcinogenicity to humans (Group 3) based on inadequate evidence in humans and sufficient evidence in experimental animals.

EPA has not published a cancer assessment of atrazine on IRIS (2003). The EPA (2002a, 2002b) Office of Pesticide Programs classified atrazine and its chlorinated metabolites (including deethylatrazine) as not likely to be carcinogenic to humans.

## A.5 Derivation of Target Organ Toxicity Dose (TTD) Values

It is recommended that the chronic PAD of 0.0018 mg/kg/day for atrazine and its chlorinated metabolites (EPA 2002b) be adopted as a provisional TTD for reproductive effects. Details of the derivation of this guidance value are as follows: A chronic RfD of 0.018 mg/kg/day was based on an oral NOAEL for atrazine of 1.8 mg/kg/day for attenuation of the LH surge and estrus cycle disruptions in female Sprague Dawley rats (EPA 2002a, 2002b). An uncertainty factor of 100 was applied to the NOAEL (10 for interspecies extrapolation and 10 for intraspecies variations). The LOAEL for these effects was 3.65 mg/kg/day. A FQPA safety factor of 10 was applied to protect infants and children when assessing dietary (food + drinking water) exposures, resulting in chronic PAD of 0.0018 mg/kg/day. The RfD and PAD are for atrazine together with its chlorinated metabolites (including deethylatrazine), which are considered to have equivalent toxicity to atrazine (EPA 2002b).

### Summary (TTD for Atrazine and Deethylatrazine)

TTD_REPRO_ = 0.0018 mg/kg/day

## A.6 References

Arbuckle TE, Lin Z, Mery LS. 2001. An exploratory analysis of the effect of pesticide exposure on the risk of spontaneous abortion in an Ontario farm population. Environ Health Perspect 109(8):851–857.11564623
ATSDR. 2003. Toxicological profile for atrazine. Post-public comment draft (version 1). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Cooper RL, Stoker TE, Tyrey L, 2000. Atrazine disrupts the hypothalamic control of pituitary-ovarian function. Toxicol Sci 53:297–307.10696778
Curtis KM, Savitz DA, Weinberg CR, 1999. The effect of pesticide exposure on time to pregnancy. Epidemiology 10:112–117.10069244
Donna A, Crosignani P, Robutti F, 1989. Triazine herbicides and ovarian epithelial neoplasms. Scand J Work Environ Health 15:47–53.
EPA. 2002a. Memorandum: Atrazine/DACT- fourth report of the hazard identification assessment review committee. Document attached. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppsrrd1/reregistration/atrazine/hed_hiarc_atrazine_5april02.PDF.
EPA. 2002b. Revised human health risk assessment: Atrazine: Memorandum attached. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppsrrd1/reregistration/atrazine/hed_redchap_16apr02.PDF.
EPA. 2002c. The grouping of a series of triazine pesticides based on a common mechanism of toxicity. Washington, DC: U.S. Environmental Protection Agency. Office of Pesticides Programs. http://www.epa.gov/oppsrrd1/cumulative/triazines/triazinescommonmech.pdf.
EPA. 2003. Pesticides. Regulating pesticides. The Food Quality Protection Act (FQPA). http://www.epa.gov/oppfead1/fqpa/backgrnd.htm.
Gilliom RJ, Barbash JE, Kolpin DW, 1999. Testing water quality for pesticide pollution: U.S. Geological Survey investigations reveal widespread contamination of the nation's water resources. Environ Sci Technol 33(7):164A–169A.
Hanioka N, Jinno H, Tanaka-Kagawa T, 1999. In vitro metabolism of chlorotriazines: Characterization of simazine, atrazine, and propazine metabolism using liver microsomes for rats treated with various cytochrome P450 inducers. Toxicol Appl Pharmacol 156:195–205.10222312
IARC. 1999a. Atrazine. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 73:59–113.10804952
IRIS. 2003. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris.
Kettles MA, Browning SR, Prince TS, 1997. Triazine herbicide exposure and breast cancer incidence: An ecologic study of Kentucky counties. Environ Health Perspect 105(11):1222–1227.9370519
Mills PK. 1998. Correlation analysis of pesticide use data and cancer incidence rates in California Counties. Arch Environ Health 53(6):410–413.9886160
Munger R, Isacson P, Hu S, 1997. Intrauterine growth retardation in Iowa communities with herbicide-contaminated drinking water supplies. Environ Health Perspect 105(3):308–314.9171992
NTP. 2003. 10th report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Savitz DA, Arbuckle T, Kaczor D, 1997. Male pesticide exposure and pregnancy outcome. Am J Epidemiol 146(12):1025–1036.9420527
Squillace PJ, Scott JC, Moran MJ, 2002. VOCs, pesticides, nitrate, and their mixtures in groundwater used for drinking water in the United States. Environ Sci Technol 36:1923–1930.12026972
Timchalk C, Dryzga MD, Langvardt PW, 1990. Determination of the effect of tridiphane on the pharmacokinetics of [^14^C]-atrazine following oral administration to male Fischer 344 rats. Toxicology 61:27–40.2315949
Van Leeuwen JA, Waltner-Toews D, Abernathy T, 1999. Associations between stomach cancer incidence and drinking water contamination. Int J Epidemiol 28(5):836–840.10597979