# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
CAS: Chemical Abstracts Service
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
CHO: Chinese hamster ovary
DACT: diaminochlorotriazine
DT: Division of Toxicology
EC_50_: median effective concentration (produces desired effect in 50% of population)
EPA: Environmental Protection Agency
FQPA: Food Quality Protection Act
GnRh: gonadotropin releasing hormone
IARC: International Agency for Research on Cancer
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LC_50_: median lethal concentration (produces desired effect in 50% of the population)
LH: luteinizing hormone
LOAEL: lowest-observed-adverse-effect level
MCL: maximum contaminant level
MCLG: maximum contaminant level goal
mg: milligram
mM: millimole
MRL: Minimal Risk Level
NADH: nicotinamide adenine dinucleotide phosphate
ng: nanogram
NOAEL: no-observed-adverse-effect level
NRC: Nuclear Regulatory Commission
NTP: National Toxicology Program
PAD: population adjusted dose
2-PAM: pralidoxime
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic/pharmacodynamic
ppb: parts per billion
RfC: reference concentration
RfD: reference dose transaminase
SMR: standardized mortality ratio
TTD: target-organ toxicity dose
μg: microgram
μmole: micromole
U.S.: United States
VOC: volatile organic compound
WOE: weight-of-evidence
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to