# 5 List of References

*Cited in text

*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry.
*ATSDR. 1995a. Toxicological profile for fuel oils. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1995b. Toxicological profile for jet fuels (JP-4 and JP-7). Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1997a. Toxicological profile for hydrazines. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1997b. Toxicological profile for trichloroethylene. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1998. Toxicological profile for JP-5 and JP-8. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2000. Toxicological profile for arsenic. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001a. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001b. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001c. Toxicological profile for strontium. Atlanta, GA: Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*Benjamin S, Yang RSH, Tessari JD, 1999. Lack of promotional effects of groundwater contaminant mixtures on the induction of preneoplastic foci in rat liver. Toxicology 137:137–139.10522494
Chapin R. 1997. Chemical mixture. Environ Health Perspect 105(1):371–372.
Chapin RE, Phelps JL, Schwetz BA, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. Fundam Appl Toxicol 13:388–398.2612772
*Constan AA, Benjamin SA, Tessari JD, 1996. Increased rate of apoptosis correlates with hepatocellular proliferation in Fischer-344 rats following long-term exposure to a mixture of groundwater contaminants. Toxicol Pathol 24(3):315–322.8736387
*Constan AA, Yang RSH, Baker DC, 1995. A unique pattern of hepatocyte proliferation in F344 rats following long-term exposures to low levels of a chemical mixture of groundwater contaminants. Carcinogenesis 16(2):303–310.7859362
Dean BJ. 1972. The mutagenic effects of organophosphorus pesticides on micro-organisms. Arch Toxicol 30:67–74.
*De Kimp J, Cornelias R, Vanholder R. 1999. In vitro methylation of arsenite by rabbit liver cystol: Effect of metal ions, metal chelating agents, methyltransferase inhibitors and uremia toxins. Drug Chem Toxicol 22:613–628.10536752
Edelfors S, Ravn-Jonsen A. 1991. Effect of organic solvents on nervous cell membranes as measured by changes in the (ca2+/mg2+) ATPase activity and fluid of synaptosomal membrane. Pharmacol Toxicol 70:181–187.
EPA. 1989. Risk assessment guidance for superfund. Volume 1. Human health evaluation manual (part A). Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA/540/1–89/002.
*EPA. 1997. Health effects assessment summary tables. Washington, DC: U.S. Environmental Protection Agency, Solid Waste and Emergency Response, EPA-540-R-97–036; PB97–92119.
*EPA. 2001. Trichloroethylene health risk assessment: synthesis and characterization. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. External Review Draft.
Germolec DR, Luster MI. 1994. Immune alterations resulting from exposure to chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. San Diego: Academic Press, 197–217.
Germolec DR, Yang RSH, Ackerman MF, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. Fundam Appl Toxicol 13:377–387.2515087
Gomez-Arroyo S, Noriega-Aldana N, Juarez-Rodriguez D, 1987. Sister chromatid exchanges induced by the organophosphorus insecticides methyl parathion, dimetoate, phoxim and methyl azinfos in cultured human lymphocytes. Contam Ambiental 3:63–70.
Grandjean P, Weihe P, Jorgensen PJ, 1992. Impact of maternal seafood diet on fetal exposure to mercury, selenium, and lead. Environ Health 47(3):185–195.
Grandjean P, Weihe P, Needham LL, 1995a. Relation of a seafood diet to mercury, selenium, and polychlorinated biphenyl and other organochlorine concentrations in human milk. Environ Res 71:29–38.8757236
Grandjean P, Weihe P, White R. 1995b. Milestone development in infants exposed to methylmercury from human milk. Neurotoxicology 16:27–34.7603642
Grandjean P, Weihe P, White R, 1997. Cognitive deficit in 7-year-old children with prenatal exposure to methylmercury. Neurotoxicol Teratol 19(6):417–428.9392777
Grandjean P, Weihe P, White RF, 1998. Cognitive performance of children prenatally exposed to "safe" levels of methylmercury. Environ Res 77:165–172.9600810
Hadler HI, Cook GL. 1979. The mitochondrial activation of sulfate and arsenate and their role in carcinogenesis. J Environ Pathol Toxicol 2:601–612.422926
Hard GC. 1998. Mechanisms of chemically induced renal carcinogenesis in the laboratory rodent. Toxicol Pathol 26(1):104–112.9502392
Harris DT, Sakiestewa D, Robledo R, 1997a. Immunotoxicological effects of JP-8 jet fuel exposure. Toxicol Ind Health 13(5):43–55.9098949
Harris DT, Sakiestewa D, Robledo R, 1997b. Protection from JP-8 jet fuel induced immunotoxicity by administration of aerosolized substance P. Toxicol Ind Health 13(5):571–588.9284531
Harris DT, Sakiestewa D, Robledo R, 1997c. Short-term exposure to JP-8 jet fuel results in long-term immunotoxicity. Toxicol Ind Health 13(5):559–570.9284530
Heindel J, Chapin RE, George J, 1995. Assessment of the reproductive toxicity of a complex mixture of 25 groundwater contaminants in mice and rats. Fundam Appl Toxicol 25:9–19.7601330
Heindel J, George J, Fail P, 1997. Chemical mixture. Environ Health Perspect 105(1):369–370.
Hong HL, Yang RSH, Boorman GA. 1991. Residual damage to hematopoietic system in mice exposed to a mixture of groundwater contaminants. Toxicol Lett 57:101–111.2048155
Hong HL, Yang RSH, Boorman GA. 1992. Alterations in hematoietic responses in B6B3F mice caused by drinking a mixture of 25 groundwater contaminants. J Environ Pathol Toxicol Oncol 11:65–74.
Hong HL, Yang RSH, Boorman GA. 1993. Enhancement of myelotoxicity induced by repeated irradiation in mice exposed to a mixture of groundwater contaminants. Arch Toxicol 67:353–364.
*IARC. 1995. Monographs on the evaluation of carcinogenic risks to humans. Vol 63. Dry-cleaning, chlorinated solvent, and other industrial chemicals. Lyons, France: International Agency for Research on Cancer, 75–158.
*IRIS. 2001. Integrated Risk Information System. http://www.epa.gov/iris/. September 04, 2001.
*Kilburn KH. 1999. Neurobehavioral and respiratory findings in jet engine repair workers: Comparison of exposed and unexposed volunteers. Ecol Res 80:244–252.
Kimpe JD, Cornelis R, Vanholder R. 1999. In vitro methylation of arsenite by rabbit liver cytosol: Effects of metal ions, metal chelating agents, methyltransferase inhibitors and uremia toxins. Drug Chem Toxicol 22(4):613–628.10536752
*Liu K, Wang G, Ma L, 1999. Adverse effects of combined arsenic and fluoride on liver and kidney in rats. Fluoride 32(4):243–247.
*NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.
Pleil JD, Smith LB, Zelnik S. 2000. Personal exposure to JP-8 jet fuel vapors and exhaust at air force bases. Environ Health Perspect 108:183–192.10706522
*Pott WA, Benjamin SA, Yang RSH. 1998. Antagonistic interactions of an arsenic-containing mixture in a multiple organ carcinogenicity bioassay. Cancer Lett 133:185–190.10072168
*Ritz B. 1999. Cancer mortality among workers exposed to chemicals during uranium processing. J Occup Environ Med 41:556–566.10412097
Rosenthal DS, Simbulan-Rosenthal CG, Liu WF, 2001. Mechanisms of JP-8 jet fuel toxicity. 1. Induction of necrosis in skin fibroblasts and keratinocytes and modulation of levels of Bcl-2 family members. Toxicol Appl Pharmacol 171:107–116.11222086
Schiller CM. 1979. Chemical exposure and intestinal function. Environ Health Perspect 33:91–100.120255
Shelby MD, Tice RR, Demarini DM, 1990. Toxicity and mutagenicity of a mixture of 25 chemicals found in contaminated groundwater. In: Vainio H, Sorsa M, McMichael AJ, eds. Complex mixtures and cancer risk. Oxford: IARC scientific publications, 314–332.
Simmons JE. 1994. Toxicology studies of a chemical mixture of 25 groundwater contaminants: Hepatic and renal assessment, response to carbon tetrachloride challenge, and influence of treatment-induced water restriction. J Toxicol Environ Health 43:305–325.7966440
*Spirtas R, Stewart PA, Lee JS, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48:515–530.1878308
*Stewart PA, Lee JS, Marano DE, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. II. Exposures and their assessment. Br J Ind Med 48:531–537.1878309
Stocia BA, Boulares AH, Rosenthal DS, 2001. Mechanisms of JP-8 jet fuel. 1. Induction of apoptosis in rat lung epithelial cells. Toxicol Appl Pharmacol 171:94–106.11222085
Tripathy NK, Dey L, Das CC. 1987. Genotoxicity of metacid established through the somatic and germ line mosiac assays and the sex-linked recessive lethal test in drosophila. Arch Toxicol 61:53–57.3125818
Twerdok LE, Burton DT, Gardner HS, 1996. The use of nontraditional assays in an integrated environmental assessment of contaminated ground water. Environ Toxicol Chem 16(9):1816–1820.
*Vodela JK, Lenz SD, Renden JA, 1997a. Drinking water (arsenic, cadmium, lead, benzene, and trichloroethylene) 2. Effects on reproductive performance, egg quality, and embryo toxicity in broiler breeders. Poult Sci 76:1493–1500.9355141
*Vodela JK, Renden JA, Lenz SD, 1997b. Drinking water contaminants (arsenic, cadmium, lead, benzene, and trichloroethylene). 1. Interaction of contaminants with nutritional status on general performance and immune function in broiler chickens. Poult Sci 76:1474–1492.9355140
Waters MD, Claxton LD, Stack HF, 1990a. Genetic activity profiles - Application in assessing potential carcinogenicity of complex environmental mixtures. In: Vainio H, Sorsa M, McMichael AJ, ed. Complex mixtures and cancer risk. Lyons, France: International Agency for Research on Cancer, 75–88.
Waters MD, Claxton LD, Stack HF, 1990b. Genetic activity profiles in the testing and evaluation of chemical mixtures. Teratog Carcinog Mutagen 10:147–164.1973853
Xamena N, Velazquez A, Batiste-Alenton M, 1998. Genotoxicity studies with four organophosphorus insecticides using the unstable white-zeste system of Drosophila melanogaster. Mutat Res 204:251–256.
*Yamamoto S, Konishi Y, Matsuda T, 1995. Cancer induction by an organic arsenic compound, dimethylarsinic acid (cacodylic acid), in F344/DUCr rats after pretreatment with five carcinogens. Cancer Res 55:1271–1276.7882321
Yang RH, Goehl TJ, Brown RD, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. Fundam Appl Toxicol 13:366–376.2612771