# SUMMARY

The mixture of jet fuels, hydrazines, trichloroethylene, arsenic, and strontium-90 was chosen to represent potential exposures in the vicinity of sites where past and/or present activities include use and/or release of these materials. Such sites might include rocket testing facilities, air force bases, and similar installations. Activities at such sites might include use of jet fuels and hydrazines as aircraft and rocket fuels and trichloroethylene as a solvent to clean engine components. Such sites sometimes include or are co-located with nuclear research facilities or radioactive waste storage sites, where strontium-90 may be found in spent nuclear fuel rods. Arsenic, although not necessarily used or produced at such sites, is frequently detected at hazardous waste sites and would not be unexpected at any specific site. The purposes of this profile are: (1) to evaluate data (if available) on the health hazards and corresponding dose-response relationships associated with exposure to this five-component mixture as a whole; (2) to evaluate data on the joint toxic actions of components of this mixture; and (3) to make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

The primary route of exposure for offsite receptors (i.e., receptors located beyond the borders of the site where the materials have been used or released) is expected to be oral for all five of these substances, resulting from contamination of soil and/or ground or surface water. Inhalation is also a potential route of exposure for jet fuels, hydrazines, and trichloroethylene, all of which are volatile. However, due to rapid degradation of hydrazine in air and dispersion of all chemicals during transport offsite, inhalation is expected to be a relatively minor route of exposure for offsite receptors under most conditions. Potential exceptions may occur when contaminated groundwater is used as household water, resulting in volatilization of the chemicals into indoor air, or when contamination of groundwater and subsurface soil results in migration of these chemicals into basements as soil gas. While inhalation is an important route of exposure to arsenic at industrial facilities that generate arsenic particulates (e.g., smelters), it is not relevant to arsenic at the sites being considered here. Catastrophic accidental release of strontium-90 to the air from nuclear facilities is possible, but is beyond the scope of this document.

No studies were located that examined health effects in humans or research animals exposed to mixtures containing jet fuels, hydrazines, trichloroethylene, arsenic, and strontium-90, and no physiologically-based pharmacokinetic/pharmacodynamic (PBPK/PD) models for this mixture have been developed. Binary weight-of-evidence (BINWOE) analysis of the joint toxic action of the component pairs was indeterminate for most pairs due to scarcity of data regarding joint toxic action of the component pairs and insufficient understanding of toxic and pharmacokinetic mechanisms of the individual substances, but did predict additivity for depression of the central nervous system from exposure to jet fuels and trichloroethylene and a greater-than-additive effect of strontium on arsenic toxicity due to inhibition by strontium of arsenic metabolism.

Although the BINWOEs were indeterminate for all of the remaining pairs due to insufficient data, the extensive overlap of toxic endpoints for the five mixture components suggests that there is a potential for joint toxic action among these substances. Therefore, it is reasonable to be cautious when evaluating public health concerns for this mixture by assuming additivity.

The hazard index approach is recommended as an additive component-based method for assessing possible health hazards from noncancer effects for mixtures of jet fuels, hydrazines, trichloroethylene, arsenic, and strontium-90. The hazard index approach allows for summing across routes of exposure to account for multiple pathways of exposure, which may be important for this mixture. For oral exposure, the lack of health guidance values is problematic and leaves only arsenic and trichloroethylene contributing to the hazard index for oral exposure to the mixture. Because these chemicals affect many of the same sensitive endpoints (neurological, renal, and immunological targets), it is recommended to calculate hazard indexes for oral exposure using both chemicals. For inhalation exposure, intermediate Minimal Risk Levels (MRLs) are available for all three chemicals for which this route is expected to potentially contribute to exposure to offsite receptors at rocket launch sites: jet fuels and hydrazines based on liver effects and trichloroethylene based on neurological effects. Because the central nervous system and the liver are sensitive targets for all three chemicals, it is recommended that inhalation hazard indexes be calculated using all three chemicals together. Application of the target-organ toxicity dose (TTD) modification of the hazard index method is not justified by the existing data set.

For cancer effects, the cancer risk for each substance (calculated from the lifetime average daily intake and the potency factor) is summed to provide an estimate of risk due to the whole mixture. Risk can be summed across routes to account for multiple pathways of exposure.

Additive approaches to assessment for this mixture are only needed when there is reason to believe that two or more chemicals in the mixture contribute significantly to the public health assessment. Therefore, hazard indexes are only calculated if two or more of the individual components have hazard quotients equaling or exceeding 0.1, and cancer risks are summed only if estimated risks exceed 1×10^−6^ for at least two components.