# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Dr. James V. Bruckner, Ph.D.
  Professor and Director of Toxicology
  University of Georgia
  College of Pharmacy
  D.W. Brooks Drive
  Athens, GA 30602
- Edwin R. Kinkead
  Retired Research Scientist
  Private Consultant
  25973 Walnut Court
  Bonita Springs, FL 34135
- Dr. Resha Putzrath, Ph.D., D.A.B.T.
  Private Consultant
  Georgetown Risk Group
  3223 N Street, N.W.
  Washington, DC 20007

All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be addressed in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this mixture. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.