# Appendix E Background Information for Strontium-90

^90^Sr is a radioisotope of strontium. ^90^Sr decays by emission of a beta-particle with a maximum energy of 0.546 millions of electron volts (MeV) and the creation of an yttrium-90 (^90^Y) radioisotope, or daughter product. Unlike other radioactive isotopes that decay by beta-emission, ^90^Sr does not directly release high energy photons or gamma-ray radiation (γ) (Brown 1997). However, the daughter product of ^90^Sr, ^90^Y, is both a beta-particle (2.28 MeV maximum energy) emitter, and to a minor degree for 0.012% of all disintegrations, a beta-particle and gamma-ray emitter. The decay product of ^90^Y is ^90^Zr, a stable isotope. The reaction is:

^90^Sr ( t_½_ = 29 years ) → ^90^Y + β^−^ ( 0 . 546 MeV ) ^90^Y ( t_½_ = 64 hours ) → ^90^Zr ( stable ) + β^−^ ( 2 . 28 MeV ) ( 99 . 989 % ) → ^90^Zr ( stable ) + β^−^ ( 0 . 519 MeV ) + γ ( 1 . 76 MeV ) ( 0 . 012 % )

## E.1 Toxicokinetics

Stable strontium and radioactive strontium do not differ with regard to disposition in the body (ATSDR 2001c). Absorption following inhalation exposure depends on the chemical form of the inhaled strontium. Soluble compounds are rapidly absorbed from the lung (within hours), while more insoluble compounds may remain in the lung for extended periods of time (years). Absorption of ingested strontium (whether in the diet or administered as soluble strontium chloride [SrCl_2_]) from the gastrointestinal tract is approximately 20% (range, 11–25%) in humans. Studies in rats suggest that absorption may be considerably higher in neonates. Within the gastrointestinal tract, absorption of strontium appears to occur in both the stomach and small intestine. Strontium is not well absorbed across intact skin, but passes much faster through scratched or abraded skin.

The distribution of absorbed strontium in the human body is similar to that of calcium, with approximately 99% of the total body burden in the skeleton. Strontium distributes relatively uniformly within the bone volume, where it exchanges with calcium in hydroxyapatite. Strontium is also found in the soft tissues, although at much lower concentrations than in bone. Strontium in the maternal skeleton can be transferred to the fetus during pregnancy. The distribution of strontium in the fetus at the end of gestation is similar to that of the mother, with most of the strontium burden in the skeleton. Strontium enters milk in humans and animals and can be transferred to newborns during breast feeding.

Strontium is not metabolized in the body. However, strontium does bind with proteins and, based on its similarity to calcium, probably forms complex formation with various inorganic anions such as carbonate and phosphate, and carboxylic acids such as citrate and lactate.

Absorbed strontium is excreted primarily in the urine and feces. Urinary excretion is approximately 3-fold higher than fecal excretion. The observation of fecal excretion of radioactive strontium weeks to decades after an oral exposure or over shorter time periods after an intravenous exposure suggests the existence of a mechanism for transfer of absorbed strontium into the gastrointestinal tract, either from the bile or directly from the plasma. During lactation, absorbed strontium is also eliminated in breast milk. The terminal elimination half-time for strontium in humans has been estimated to be approximately 25 years. Estimates of the terminal elimination half-times of strontium reflect primarily the storage and release of strontium from bone. Over shorter time periods after exposure, faster elimination rates are observed that reflect soft-tissue elimination as well as elimination from a more rapidly exchangeable pool of strontium in bone.

## E.2 Health Effects

The basis of the adverse effects of ionizing radiation on human or animal tissue is the direct interaction of free radicals with cellular macromolecules, including DNA (ATSDR 2001c). Low-level exposures are not necessarily harmful, as shown by the lack of discernable adverse effects in the general population from chronic low-level exposure to ^90^Sr in fallout during the period of above ground weapons testing. Exposures to radioactive strontium become harmful when the amount of radiation damage exceeds the capacity of natural cellular repair mechanisms. External exposure to radioactive strontium has resulted in dermal and ocular effects in humans. Since absorbed radiostrontium is preferentially retained in bone, and therefore has a long biological half-life, all exposures leading to the presence of radiostrontium in the body, of whatever duration, will lead to chronic internal exposure to ionizing radiation. Consequently, the most significant effects of exposure to absorbed radioactive strontium are necrosis and cancers of bone, bone marrow, and tissues adjacent to bone. High level acute exposures can lead to acute radiation sickness resulting from destruction of the hematopoietic bone marrow. Dystrophic or osteolytic lesions have been described in humans and animals following intermediate or chronic exposures. At lower levels of exposure, chronic suppression of immune function has been observed in humans and animals. In animal studies, inhalation of insoluble particles of radioactive strontium led to retention in the lung and resulted in pulmonary necrosis and cancer. The young are more susceptible to adverse effects of absorbed radioactive strontium because of their higher rates of gastrointestinal absorption and of strontium retention in the immature skeleton. High prenatal exposure levels may cause major developmental anomalies in the skeleton and adjacent areas if critical tissues are destroyed. In addition, since children have a higher proportion of mitotic cells than adults, they may exhibit higher rates of cancer (genetic lesions become fixed mutations when mitosis occurs before genetic damage is repaired). Persons with Paget’s disease (osteitis deformans) may be vulnerable to radioactive strontium because of their higher than normal rates of retention in focal sites of bone deposition.

## E.3 Mechanisms of Action

The adverse health effects of radioactive strontium are related to its sequestration in bone, the high energy of its beta emissions, and in the case of ^90^Sr, its long half-life (ATSDR 2001c). An extensive discussion of ionizing radiation and its health effects is found in the Toxicological Profile for Ionizing Radiation (ATSDR 1999). Beta emissions from radiostrontium bound to bone have resulted in various bone lesions (trabecular osteoporosis, sclerosis, osteolytic lesions), particularly in animals that were exposed chronically. In young rats and rabbits exposed orally to ^90^Sr, necrotic effects on the vasculature of developing bone secondarily disrupted the process of osteogenesis. Disruption in the metaphyseal microvasculature disorganized the transformation of cartilage into bone, so that chondrocytes inappropriately resumed active proliferation. Severe reduction in hematopoietic tissue results from irradiation of the bone marrow by radiostrontium incorporated into bone. At high exposure levels, thrombocytopenia may lead to platelet loss severe enough to cause hemorrhaging; the resulting anemia will be exacerbated by destruction of erythropoietic tissue. Impaired immune function results from the genetic damage to lymphocytes.

Radioactive strontium is a genotoxic carcinogen. Following exposure in vivo, cytogenetic analysis has revealed aneuploidy, chromosomal breaks, gaps, rings, and exchanges, which are manifestations of unrepairable changes in DNA. It is generally understood that radiation-induced damage to genes that regulate cell growth is a major factor in the development of cancer in affected cells, and the observation of chromosomal breaks in leukemic cells of miniature swine following chronic oral exposure to ^90^SrCl_2_ is consistent with this idea. However, the specific genes involved in radiostrontium-induced malignancies have not been identified. Because of strontium’s chemical properties, which determine its distribution in the body, exposure to sufficient radiostrontium results in an increased risk of malignancy for particular tissues. In dogs, acute inhalation of insoluble ^90^Sr particles that lodged in the lungs resulted in chronic radiation exposure to the lungs, leading to pulmonary hemangiomas and carcinomas of pulmonary epithelia. Other tissues were subsequently affected as the radioactive particles were cleared from the lungs. Following acute inhalation of soluble ^90^SrCl_2_ aerosols, some dogs developed carcinomas of nasal airway tissues, probably resulting from irradiation of these tissues from the ^90^Sr bound to the underlying bone. Following oral or inhalation exposures, absorbed ^90^Sr was distributed to bone, from which it irradiated the surrounding tissues and induced various kinds of osteosarcomas, as well as malignancies of hematopoietic tissues in bone marrow.

## E.4 Health Guidelines

No MRLs were derived for inhalation or oral exposures to radioactive strontium (ATSDR (2001c). The EPA has not derived an RfC or RfD for radioactive strontium (IRIS 2001). IARC has determined that all internally deposited beta emitters, including radioactive strontium, are carcinogenic to humans and has assigned them to Group 1 (IARC 2001). Radioactive strontium is not included in NTP’s 9^th^ Report on Carcinogens (2001). The EPA has determined that all radionuclides, including radioactive strontium, are known human carcinogens, and has assigned them to Group A (EPA 1997). The EPA (1997) has calculated carcinogenicity slope factors (upper bound lifetime risk per pCi) for ^90^Sr for ingestion (4.09×10^−11^ for ^90^Sr and 5.59×10^−11^ for ^90^Sr plus disintegration products) and inhalation (5.94×10^−11^ for ^90^Sr and 6.93×10^−11^ for ^90^Sr plus disintegration products).

## E.5 References

ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2001c. Toxicological profile for strontium. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Brown E. 1997. Nuclear data sheet.. 82:379. Http://hpngp01.kaer1.re.kr/cgi-bin/decay?Y90+B- (http://hpngp01.kaer1.re.kr/cgi-bin/decay?Y90+B).
EPA. 1997. Health effects assessment summary tables. Washington, DC: U.S. Environmental Protection Agency, Solid Waste and Emergency Response. EPA-540-R-97–036. PB97–92119.
IARC. 2001. Some internally deposited radionuclides. Lyons, France: International Agency for Research on Cancer. http://193.51.164.11/htdocs/monographs/vol78/vol78-radionuclides.html. May 1, 2001.
IRIS. 2001. Integrated Risk Information System. http://www.epa.gov/iris/. September 04, 2001.
NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.