# Appendix D Background Information for Arsenic

## D.1 Toxicokinetics

Arsenic, as water soluble arsenate or arsenite, is well-absorbed (≥80%) in both humans and animals exposed by the oral route (ATSDR 2000; NRC 1999). Judging from the oral toxicity data, arsenic trioxide also is well absorbed. Lower rates of absorption have been observed with insoluble or less soluble forms of arsenic, such as arsenic sulfide and lead arsenate. Absorption appears to occur by passive diffusion. Distribution occurs throughout the body. Concentrations in skin of humans exposed to background levels of arsenic are higher than in other tissues except blood. Arsenic accumulates in the skin of animals following long-term exposure. Concentrations in hair and nails tend to be higher than in live tissues. The rat tends to sequester arsenic in erythrocytes. Arsenates (As[V]) and arsenites (As[III]) are interconverted in the body by reduction/oxidation reactions. Reduction of arsenate to arsenite can be mediated by glutathione. Arsenite is methylated to yield the less toxic forms monomethylarsenite and dimethylarsenite. The liver is the major site for the methylation. Arsenic is promptly eliminated in the urine as a mixture of As(III), As(V), and the methylated forms. Smaller amounts are excreted in the feces.

## D.2 Health Effects

Chronic oral exposure to arsenic has resulted in serious damage to the vascular system in humans, including Blackfoot disease (a progressive loss of circulation in the fingers and toes that may lead to gangrene), Raynaud’s disease, and cyanosis of fingers and toes (ATSDR 2000; NRC 1999). The intima of the blood vessels appeared to have thickened. Direct irritation of the gastrointestinal mucosa can occur. Arsenic has caused anemia in humans exposed by the oral route. Increased hemolysis and a toxic effect on the erythropoietic cells of bone marrow may be factors in the development of anemia. Leukopenia has been reported in humans. Hepatic effects seen in humans were thought to be secondary to portal tract fibrosis and portal hypertension, which may have originated from damage to the blood vessels. Signs of renal damage generally are not seen or are mild in humans exposed to arsenic by the oral route. Characteristic dermal lesions caused by long-term oral exposure of humans to arsenic include hyperkeratinization (particularly on the palms and soles), formation of hyperkeratinized corns or warts, and hyperpigmentation of the skin with associated spots of hypopigmentation. A fraction of the hyperkeratinized corns may progress to squamous cell carcinoma of the skin. Signs of peripheral and/or central neuropathy are commonly seen in humans exposed to arsenic orally, with high-dose exposure producing central nervous system effects and low-dose exposure producing peripheral nervous system effects. The potential for arsenic to cause subtle neurological effects, such as neurobehavioral effects in children, has not been fully investigated. Studies of associations between hair arsenic concentrations (a biomarker of exposure) and neurobehavioral effects in children have observed an inverse association between hair arsenic and reading and spelling performance (Moon et al. 1985). Children may be especially susceptible to arsenic because there is evidence that metabolism (i.e., detoxification) of arsenic may be less efficient in children and because arsenic’s ability to inhibit cellular proliferation might be especially problematic in rapidly growing young children.

Effects on the skin, vascular system, and neurological system appear to be relatively sensitive effects of ingested arsenic; dermal effects are the best documented sensitive effect and the earliest observable sign of health effects from long-term exposure (ATSDR 2000; NRC 1999). The no-observed-adverse-effect level (NOAEL) and LOAEL for dermal effects in humans are 8×10^−4^ and 0.014 mg/kg/day, respectively. Hematological effects may be somewhat less sensitive, and renal effects even less sensitive and less common. Epidemiological studies provide convincing evidence that ingestion of arsenic causes cancer of the skin in humans. The lesions include squamous cell carcinomas, which develop from some of the hyperkeratotic warts or corns, and multiple basal cell carcinomas, arising from cells not associated with hyperkeratinization. Evidence is mounting that ingested arsenic may increase the risks of internal cancers as well (NRC 2001).

Some of the effects of arsenic seen in humans are supported by animal data, but animals do not develop dermal lesions and cancer as a result of oral arsenic exposure. Changes in vascular reactivity have been reported in rats given repeated oral arsenic doses of 11 mg/kg/day (ATSDR 2000). Hematological and hematopoietic effects, including decreased hematocrit and increased urinary excretion of porphyrins, have been observed in intermediate-duration dietary studies of arsenic in rats at doses of 2.5 mg/kg/day (Fowler and Mahaffey 1978; Mahaffey et al. 1981), and in chronic oral studies in dogs at 2.4 mg/kg/day (ATSDR 2000). Intermediate oral studies in rats demonstrated alterations in renal mitochondria at 2.5 and 4.7 mg/kg/day (ATSDR 2000; Mahaffey and Fowler 1977; Mahaffey et al. 1981). Mild proteinuria was observed in rats following a single oral dose of 10 mg/kg (ATSDR 2000). Repeated oral administration of arsenic to mice at 11 mg/kg/day altered neurotransmitter concentrations in some areas of the brain (Mejia et al. 1997). Developmental effects have been seen following high oral doses of arsenic in animals, but these are not sensitive effects (ATSDR 2000).

## D.3 Mechanisms of Action

At relatively high oral exposures, methylation capacity may not be adequate to prevent cytotoxic levels of arsenic(III) from reaching tissues. Some of the effects of higher-dose oral exposure to arsenic are thought to be the result of direct cytotoxicity; these include gastrointestinal irritation, and dermal and neurological effects (ATSDR 2000). Arsenic(III) reacts with the sulfhydryl groups of proteins, inactivates enzymes, and interferes with mitochondrial function by inhibiting succinic dehydrogenase activity and uncoupling oxidative phosphorylation. It has been proposed that arsenic may compete with phosphate during oxidative phosphorylation and may inhibit energy-linked reduction of nicotinamide adenine dinucleotide (Goyer 1995). Chronic low-level exposure to arsenic is thought to stimulate keratinocyte secretion of growth factors; the resulting increase in cell division and DNA replication affords greater opportunities for genetic damage. Arsenic induces metallothionein, a metal-binding protein. Only a small percentage of administered arsenic is bound to metallothionein, and the affinity of arsenic for metallothionein is much lower than that of cadmium or zinc (ATSDR 2000). It has been suggested that metallothionein may protect against arsenic toxicity by acting as an antioxidant against oxidative injury produced by arsenic (ATSDR 2000; NRC 1999).

## D.4 Health Guidelines

ATSDR (2000) did not derive inhalation MRLs or an intermediate oral MRL for arsenic due to lack of suitable studies. ATSDR (2000) derived a provisional acute oral MRL of 0.005 mg/kg/day for arsenic based on a LOAEL of 0.05 mg/kg/day for facial (periorbital) edema and gastrointestinal irritation in poisoning cases from arsenic-contaminated soy sauce in Japan (Mizuta et al. 1956). These effects were the initial effects, and in some patients, were followed by dermal lesions, neuropathy (hypesthesia in legs, abnormal patellar reflex), mild anemia, mild degenerative liver lesions and hepatic dysfunction, and abnormal electrocardiogram. An uncertainty factor of 10 was applied to account for the use of a LOAEL. The MRL is considered provisional because the gastrointestinal effects were serious and because serious neurological and cardiovascular effects also occurred at the same dose. ATSDR (2000) derived a chronic oral MRL of 3×10^−4^ mg/kg/day for arsenic based on a NOAEL of 8×10^−4^ mg/kg/day for dermal lesions in male and female farmers exposed to high levels of arsenic in well water in Taiwan. An uncertainty factor of 3 was applied to account for human variability.

EPA has not derived an RfC for arsenic (IRIS 2001). EPA (IRIS 2001) derived a chronic RfD of 3×10^−4^ mg/kg/day for arsenic based on a NOAEL of 8×10^−4^ mg/kg/day for dermal lesions and possible vascular complications for farmers in Taiwan, which also was used as the basis for the ATSDR chronic oral MRL. An uncertainty factor of 3 was applied to account for the lack of reproductive data and to account for some uncertainty in which the NOAEL in the critical study accounts for all potentially sensitive individuals.

NTP (2001) has determined that inorganic arsenic compounds are known to be human carcinogens, based on sufficient evidence of carcinogenicity in humans. IARC (1987) concluded that there is sufficient evidence of a relationship between exposure to arsenic and human cancer, and classifies arsenic in Group 1. The American Conference of Governmental Industrial Hygienists (ACGIH) classifies arsenic (elemental and inorganic compound) as a confirmed human carcinogen; cancer category A1 (ACGIH 1998). EPA (IRIS 2001) has classified arsenic in Group A (human carcinogen), based on increased lung cancer mortality in several human populations exposed primarily through inhalation, increased mortality from internal organ cancers (liver, kidney, lung, and bladder), and increased incidences of skin cancer in populations exposed to arsenic through drinking water. An oral slope factor of 1.5 per (mg/kg)/day was derived based on analysis of the skin cancer data from a Taiwanese population exposed through drinking water. An inhalation unit risk of 4.3×10^−3^ per μg/m^3^ was derived based on age-specific mortality from lung cancer in male smelter workers.

## D.5 References

ACGIH. 1998. Threshold limit values for chemical substances and physical agents. Biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH. (As cited in ATSDR 2000).
ATSDR. 2000. Toxicological profile for arsenic. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Fowler BA, Mahaffey KR. 1978. Interactions among lead cadmium and arsenic in relation to porphyrin excretion. Environ Health Perspect 25:87–90.720307
Goyer RA, Klaasen CD, Waalkes MP, eds. 1995. Metal Toxicology. San Diego, California: Academic Press, 525p.
IARC. 1987. Arsenic and arsenic compounds. Lyons, France: International Agency for Research on Cancer.
IRIS. 2001. Integrated Risk Information System. http://www.epa.gov/iris/. September 04, 2001.
Mahaffey KR, Fowler BA. 1977. Effects of concurrent administration of lead and cadmium and arsenic in the rat. Environ Health Perspect 19:165–171.198203
Mahaffey KR, Capar SG, Gladen BC, 1981. Concurrent exposure to lead, cadmium and arsenic. Effects on toxicity and tissue metal concentrations in the rat. J Lab Clin Med 98(1):463–481. (As cited in ATSDR 2000).7288264
Mejia JJ, Diaz-Barriga F, Calderon J, 1997. Effects of lead-arsenic combined exposure on central monoaminergic systems. Neurotoxicol Tetratol 19(6):489–497.
Mizuta N, Mizuta M, Ito F, 1956. An outbreak of acute arsenic poisoning caused by arsenic-contaminated soy-sauce (shoyo): A clinical report of 220 cases. Bull Yamaguchi Med Sch 4(2–3):131–149. (As cited in ATSDR 2000).
Moon C, Marlowe M, Stellern, 1985. Main and interaction effects of metallic pollutants on cognitive functioning. J Learn Disabil 18(4):217–221.3989363
NRC. 1999. Arsenic in drinking water. National Research Council. Washington, DC: National Acacdemy Press.
NRC. 2001. Arsenic in drinking water: 2001 update. National Research Council. Washington, DC: National Academy Press.
NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.