# Appendix C Background Information for Trichloroethylene

## C.1 Toxicokinetics

Trichloroethylene is rapidly and extensively absorbed following inhalation, oral, and dermal exposure (ATSDR 1997b; EPA 2001). Once absorbed, trichloroethylene is widely distributed to organs throughout the body (including the developing fetus) and, due to its lipophilic properties, accumulates in fat. Metabolism of trichloroethylene is extensive and occurs primarily in the liver, but also in the kidney, lungs, and other tissues. Biotransformation pathways in humans are thought to be qualitatively similar to those identified in animals. Two major pathways have been identified: (1) oxidation and (2) conjugation with glutathione. The initial, rate-limiting step in the oxidative pathway is oxidation by several isozymes of cytochrome P-450 to chloral hydrate. Chloral hydrate is then either oxidized to trichloroacetic acid via chloral hydrate dehydrogenase or reduced to trichloroethanol via alcohol dehydrogenase. Trichloroethanol undergoes conjugation with glucuronic acid to form trichloroethanol-glucuronide. The glucuronide can be eliminated in the urine or can be excreted to the bile and reabsorbed from the small intestine. This enterohepatic circulation is more prominent in humans than in rodents. Another metabolite that has been found in mice and humans is dichloroacetic acid, possibly formed by oxidation of trichloroacetic acid and/or trichloroethanol. The second pathway of trichloroethylene metabolism starts with glutathione conjugation in the liver to form S-(1,2-dichlorovinyl)glutathione, which is excreted in the bile and converted in the bile and intestines to S-(1,2-dichlorovinyl)-L-cysteine, which is reabsorbed by the body and concentrated in the kidney, where it can be detoxified by N-acetyltransferase and excreted in the urine or activated to a thioacetylating agent by β-lyase. This second pathway becomes especially important when high levels of trichloroethylene are present and the oxidative metabolism becomes saturated. Trichloroethylene is eliminated from the body predominately in the urine as metabolites (trichloroethanol, trichloroethanol-glucuronide, and trichloroacetic acid) and to a lesser degree in exhaled breath as the parent chemical or other volatile metabolites such as trichloroethanol and carbon dioxide.

Pharmacokinetic models have been developed for the disposition of trichloroethylene in mice, rats, and humans, including the prediction of target organ (e.g., liver, lung, brain, kidney) doses of biologically-active metabolites (Clewell et al. 2000; Fisher 2000; Fisher et al. 1998). These models have been used to investigate differences in metabolism among species. Such differences include higher peak blood levels of oxidative metabolites (e.g., trichloroacetic acid) in mice and rats than humans at equivalent doses, and longer duration of elevated blood levels in humans (ATSDR 1997b; EPA 2001). Species differences in enterohepatic circulation are thought to contribute to these differences. In vitro data suggest that the glutathione conjugation to form S-(1,2-dichlorovinyl)glutathione occurs more rapidly in mice than in rats or humans. However, it has not been established that subsequent steps in this pathway also occur more rapidly in mice.

## C.2 Health Effects

Targets for trichloroethylene noncarcinogenic toxicity include the central nervous system (central nervous system depression, neurobehavioral deficits, hearing loss), liver (changes in serum cholesterol and bile acids, liver enlargement, cellular hypertrophy), kidneys (increased kidney weights, cytomegaly and karyomegaly in renal tubular epithelial cells), heart (decreased heart rate, cardiac arrhythmia), endocrine system (altered hormone levels), immune system (depressed immune function, autoimmune disease), male reproductive system (decreases in sperm count and motility), and developing fetus (cardiac and eye malformations, neurobehavioral alterations) (ATSDR 1997b; EPA 2001). The most sensitive endpoints following subchronic/chronic oral exposure were the liver, kidney, and developing fetus, with effects at doses down to 1–10 mg/kg/day. Following subchronic/chronic inhalation exposure, the most sensitive endpoints were the central nervous system, liver, and endocrine system, with effects at concentrations down to 1–100 ppm.

A recent article (Wartenberg et al. 2000) reviewed over 80 published papers and letters on the epidemiology of cancer in groups of people occupationally exposed to trichloroethylene. Based on analysis of the studies with the most rigorous exposure assessments, relative risks were elevated for kidney cancer (RR=1.7, 95% CI=1.1–2.7), liver cancer (RR=1.9, 95% CI=1.0–3.4), and non-Hodgkin’s lymphoma (RR=1.5, 95% CI=0.9–2.3) in several cohorts of workers repeatedly exposed to high concentrations of trichloroethylene for years in workplace air. Workers in these studies, however, were also exposed to other solvents (e.g., tetrachloroethylene). Accurate adjustment for this and other confounding factors is not possible from the available data. Wartenberg et al. (2000) concluded that there is “moderate support” for a causative relationship between exposure to trichloroethylene and cancer using Hill’s criteria of causation. Extensive testing in animals has shown mice developing liver and lung tumors and lymphomas, and rats developing kidney and testicular tumors (ATSDR 1997b; EPA 2001).

## C.3 Mechanisms of Action

Nervous system effects from trichloroethylene, as for other lipophilic solvents, are thought to involve disruption of functions of neural membranes by the physical presence of the parent chemical in the neuronal membrane (ATSDR 1997b; EPA 2001). There is evidence to suggest that metabolites, such as trichloroethanol and dichloroacetic acid, may also contribute to the observed neurological effects. Trichloroethylene-induced cardiac arrhythmias are thought to involve parent-chemical sensitization of the heart to epinephrine-induced arrhythmias. In animals, chemicals that inhibited the metabolism of trichloroethylene increased the potency of trichloroethylene to induce cardiac arrhythmias, whereas chemicals enhancing trichloroethylene metabolism decreased its potency.

Carcinogenic and noncarcinogenic toxic effects of trichloroethylene in the liver and kidney are thought to be related to metabolism of the parent compound and production of reactive metabolites and intermediates (ATSDR 1997b; EPA 2001; Goeptar et al. 1995). Reactive metabolites of the oxidative metabolic pathway that have been implicated in the production of liver effects include chloral hydrate, trichloroacetic acid, and dichloroacetic acid. Hypotheses that have been put forward for effects of these metabolites in the liver include peroxisome proliferation (oxidative damage caused by increases in free-radical generating enzymes and peroxisomal β-oxidation lead to tumor formation by an unknown mechanism; most closely associated with trichloroacetic acid; has not been observed in humans), responses mediated by the peroxisome proliferator-activated receptor (leads to promotion of gene transcription, including enzymes important in lipid metabolism; most closely associated with trichloroacetic acid; qualitatively similar in humans and mice), disturbances in cell signaling (alterations in cell replication, selection, and apoptosis; affected in different ways by trichloroacetic acid and dichloroacetic acid), and effects on DNA (altered gene expression [e.g., hypomethylation of DNA leading to modified transcription of the gene] rather than induced mutation [trichloroethylene and its oxidative metabolites are weak genotoxicants]; associated with both trichloroacetic acid and dichloroacetic acid). EPA (2001) concluded that liver effects following trichloroethylene exposure may be due to both trichloroacetic acid and dichloroacetic acid acting by multiple modes of action.

Trichloroethylene-induced kidney damage has been proposed to involve conjugation products of trichloroethylene with glutathione. The conjugated products (e.g., dichlorovinyl-cysteine) can be hydrolyzed by β-lyase in the kidney, forming a reactive thiol group that can react with cellular macromolecules and lead to cell damage. These cysteine intermediates have been shown to induce point mutations in bacteria. In support of this mechanistic hypothesis, chemical agents that inhibit β-lyase protected against dichlorovinyl-cysteine nephrotoxicity in rats.

Little is known about how trichloroethylene and/or its metabolites produce endocrine, immune, reproductive, and developmental effects, although some of the same mechanisms proposed for the liver, such as interference with cell signaling and activation of peroxisome proliferator-activated receptor, may be relevant to these other organ systems.

## C.4 Health Guidelines

ATSDR (1997b) derived an acute inhalation MRL of 2 ppm (10 mg/m^3^) for trichloroethylene based on a LOAEL of 200 ppm for subjective neurological symptoms such as fatigue and drowsiness in volunteers exposed 7 hours/day for 5 days. An uncertainty factor of 100 (10 for the use of a LOAEL and 10 to account for human variability) was used in the calculation. ATSDR (1997b) also derived an intermediate-duration inhalation MRL of 0.1 ppm (0.5 mg/m^3^) for trichloroethylene based on a LOAEL of 50 ppm for decreased wakefulness during exposure, decreased postexposure heart rate, and slow-wave sleep in rats exposed for 8 hours/day, 5 days/week for 6 weeks. An uncertainty factor of 300 (10 for using a LOAEL, 3 for extrapolating from rats to humans, and 10 to account for human variability) was employed. ATSDR (1997b) did not derive a chronic inhalation MRL for trichloroethylene due to the lack of suitable data. EPA (2001) derived a draft chronic inhalation RfC of 0.04 mg/m^3^ for trichloroethylene based on central nervous system effects in two occupational studies with estimated exposure concentrations of 7 ppm (38 mg/m^3^) and an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for subchronic exposure, and 10 for protection of sensitive individuals).

ATSDR (1997b) derived an acute oral MRL of 0.2 mg/kg/day for trichloroethylene based on a LOAEL of 50 mg/kg/day for neurobehavioral effects in mouse pups and an uncertainty factor of 300 (10 for the use of a LOAEL, 10 for extrapolating from animals to humans, and 3 for human variability [a full factor of 10 was not used because pups were taken to represent a sensitive population]). ATSDR (1997b) did not derive intermediate or chronic oral MRLs due to lack of appropriate data. EPA (2001) derived a draft chronic oral RfD of 2×10^−4^ mg/kg/day based on adverse liver effects at a human equivalent dose of 1 mg/kg/day in two species in subchronic studies and an uncertainty factor of 5,000 (10^½^ for extrapolation from animals to humans, 10^½^ for use of a subchronic study, 10^½^ for use of a LOAEL, 50 to protect sensitive individuals, and a modifying factor of 10^½^ to reflect background exposure to trichloroethylene and its metabolites).

EPA (2001) characterized the weight of evidence for trichloroethylene as “highly likely to be carcinogenic to humans” under the proposed guidelines and “probable human carcinogen” (Group B1) under the current guidelines, based on limited human evidence from the joint analysis of epidemiology papers by Wartenberg et al. (2000), sufficient evidence in animals, and mechanistic information suggesting that trichloroethylene’s mode of action may be relevant to humans. EPA (2001) calculated draft oral slope factors from data for a variety of tumors in humans and animals; after discounting the data showing the lowest risks (studies in rats, which appear to be less sensitive than humans or mice) and the highest risk (from a human inhalation epidemiology study based on a small number of cases and an uncertain exposure estimate), EPA concluded that confidence is greatest in the central risk estimates 0.02–0.4 per mg/kg/day (from human occupational inhalation data for kidney cancer, human oral environmental data for lymphoma, and mouse data for liver cancer). The corresponding inhalation unit risk from the human occupational data for kidney cancer was 5×10^−6^ per (μg/m^3^). Similar conclusions regarding weight of evidence were reached in other recent assessments of trichloroethylene carcinogenicity. NTP (2001) listed trichloroethylene as reasonably anticipated to be a human carcinogen based on limited evidence of carcinogenicity from studies in humans, sufficient evidence of malignant tumor formation in experimental animals, and convincing relevant information that trichloroethylene acts through mechanisms indicating it would likely cause cancer in humans. IARC (1995) assigned trichloroethylene to Cancer Group 2A, probably carcinogenic to humans, based on limited evidence in humans and sufficient evidence in experimental animals.

## C.5 References

ATSDR. 1997b. Toxicological profile for trichloroethylene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Clewell HJ, Gentry PR, Covington TR, 2000. Development of a physiologically based pharmacokinetic model of trichloroethylene and its metabolites for use in risk assessment. Environ Health Perspect 108:283–305.
EPA. 2001. Trichloroethylene health risk assessment: synthesis and characterization. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. External Review Draft.
Fisher JK. 2000. Physiologically based pharmacokinetic models for trichloroethylene and its oxidative metabolites. Environ Health Perspect 108:265–273.
Fisher JW, Mahle D, Abbas R. 1998. A human physiologically based pharmacokinetic model for trichloroethylene and its metabolites, trichloroacetic acid and free trichloroethanol. Toxicol Appl Pharmacol 152:339–359.9853003
Goeptar AR, Commandeur JNM, van Ommen B, 1995. Metabolism and kinetics of trichloroethylene in relation to toxicity and carcinogenicity. Relevance of the mercapturic acid pathway. Chem Res Toxicol 8:3–21.7703363
IARC. 1995. Monographs on the evaluation of carcinogenic risks to humans. Vol 63. Dry-cleaning, chlorinated solvent, and other industrial chemicals. Lyons, France: International Agency for Research on Cancer, 75–158.
NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.
Wartenberg D, Reyner D, Scott CS. 2000. Trichloroethylene and cancer: Epidemiologic evidence. Environ Health Perspect 108(2):161–176.10807550