# Appendix B Background Information for Hydrazine Compounds

The hydrazine compounds included in this Interaction Profile are hydrazine (diamine) and 1,1-dimethylhydrazine (unsymmetrical dimethylhydrazine), both of which have been used as rocket fuels. These chemicals are similar with regard to disposition in the body and health effects and will be discussed together below.

## B.1 Toxicokinetics

Animal studies suggest that hydrazines are well absorbed following inhalation, oral, or dermal exposure, and are evenly distributed throughout the body without preferential accumulation in any specific tissues (ATSDR 1997a). Metabolism of hydrazines involves a number of enzymatic and non-enzymatic pathways, and differs somewhat for hydrazine and 1,1-dimethylhydrazine. In vivo studies in rats have shown that hydrazine undergoes acetylation and can react with cellular molecules. Metabolism of this compound is qualitatively similar by different routes of exposure. Observed metabolites include acetyl hydrazine, diacetyl hydrazine, pyruvate hydrazone, and urea in the urine, and nitrogen gas in the expired air. In vitro studies have shown that hydrazine is readily metabolized by cytochrome P-450 in rat liver and can also be a substrate for other enzyme systems (peroxidases) or nonenzymatic reactions (copper ion-mediated). Oxidative metabolism of hydrazine is accompanied by formation of free radicals, including acetyl, hydroxyl, and hydrogen radicals. The presence of acetyl radicals suggests that hydrazine is acetylated prior to radical formation. Metabolism of 1,1-dimethylhydrazine also results in generation of free radicals, but with this compound, methyl radicals are produced during oxidative demethylation (enzymatic or nonenzymatic) to formaldehyde. In vivo studies have found hydrazone derivatives of 1,1-dimethylhydrazine in the urine. Although both hydrazine compounds are readily metabolized, a fair amount of both is excreted unchanged in the urine. Elimination of metabolites and parent compound is rapid, with most of the absorbed dose being eliminated from the body within 24 hours.

## B.2 Health Effects

The central nervous system is the most prominent target of hydrazines that has been identified in humans (ATSDR 1997a). Effects, which have been recorded after inhalation, oral, and dermal exposure, have included nausea, vomiting, dizziness, excitement, tremors, polyneuritis, impaired cognitive function, lethargy, narcosis, convulsions, and coma. Animal studies have confirmed that the central nervous system is an important target of hydrazine and 1,1-dimethylhydrazine. The effects that have been noted are similar to those observed in humans: behavioral changes, tremors, depression, lethargy, seizures, and convulsions. Very limited human data have also suggested that inhalation of hydrazines can affect the lungs (bronchitis, tracheitis, pneumonia, dyspnea, pulmonary edema), heart (atrial fibrillation, enlargement of the heart, degeneration of heart muscle fibers), liver (fatty degeneration, focal necrosis), and kidney (tubular necrosis, hemorrhage, inflammation). Animal studies support these tissues as target organs for hydrazines. Hydrazine and 1,1-dimethylhydrazine have been reported to produce irritation, inflammation, hyperplasia, dysplasia, and cellular damage in the nasal mucosa and lungs of rodents by inhalation exposure. Studies have demonstrated multiple liver effects (hemosiderosis, degeneration, fatty change, elevated serum enzyme levels, hyperplasia, necrosis, hepatitis, fibrosis) due to hydrazine and 1,1-dimethylhydrazine in multiple species by inhalation, oral, and parenteral routes of exposure. Renal effects have also been observed in animal studies, although effects were mild in most cases. Injected hydrazine did produce more severe effects (nephritis) in studies in dogs and monkeys. Animal data on cardiovascular effects are inconsistent, but there are reports of angiectesis (dilated blood vessels) and altered blood pressure after exposure to 1,1-dimethylhydrazine and myocardial fat accumulation after injection with hydrazine.

Hydrazines can produce contact dermatitis in humans. Animal studies have also reported dermal and ocular irritant effects after direct contact. Animal studies have also shown that hydrazines can produce hematological effects (e.g., anemia) in dogs (but not in rodents or monkeys) and have presented limited evidence for effects on the immune system (decreased T-helper cells in vivo, immunomodulation in mouse splenocytes and lymphocytes in vitro), reproduction (ovarian and testicular atrophy, endometrial inflammation and cysts, aspermatogenesis, abnormal sperm), and development (reduced fetal body weights, perinatal mortality in one injection study but not in other studies). There is ample evidence that hydrazine and 1,1-dimethylhydrazine are genotoxic, producing methyl adducts in DNA and positive results in a series of assays for mutagenicity, micronucleus formation, sister chromatid exchange, unscheduled DNA synthesis, and cell transformation. Both hydrazine and 1,1-dimethylhydrazine are carcinogenic in rodents, producing multiple tumor types after inhalation, oral, and parenteral exposure.

## B.3 Mechanisms of Action

Hydrazines may produce adverse effects by two different mechanisms (ATSDR 1997a). First, hydrazines that have a free amino group (including both hydrazine and 1,1-dimethylhydrazine) can bind directly to cellular molecules. For example, hydrazines can react with endogenous alpha-keto acids to form hydrazones. The consequences can be illustrated by the case of vitamin B6. Hydrazine and 1,1-dimethylhydrazine can form hydrazones with vitamin B6 derivatives, thereby inhibiting reactions that require vitamin B6 as a cofactor (e.g., transamination reactions, decarboxylation of amino acids, metabolism of lipids and nucleic acids, and glycogen phosphorylation) and inducing a functional deficiency of vitamin B6, which can lead to convulsions, anemia, and dermatitis. Convulsions and other neurological effects are known to be associated with exposure to hydrazines. Patients are commonly treated with a form of vitamin B6 (pyridoxine). Second, metabolism of hydrazines results in generation of reactive free radical intermediates. Binding of reactive intermediates may explain the genotoxic effects of hydrazines and may serve as the initiating event for cancers induced by hydrazines.

## B.4 Health Guidelines

ATSDR (1997a) derived intermediate inhalation MRLs of 0.004 ppm (0.005 mg/m^3^) for hydrazine and 2×10^−4^ ppm (5×10^−4^ mg/m^3^) for 1,1-dimethylhydrazine, based on LOAELs of 0.2 and 0.05 ppm, respectively, for liver effects in female mice exposed intermittently for 6 months (moderate fatty change for hydrazine, hyaline degeneration of the gall bladder for 1,1-dimethylhydrazine). Data were inadequate to support acute or chronic inhalation MRLs or oral MRLs. EPA has not derived RfD or RfC values for hydrazine or 1,1-dimethylhydrazine (EPA 1997; IRIS 2001). Both compounds are classified in IARC cancer Group 2B (possible human carcinogen) (IARC 2001) and listed as reasonably anticipated to be human carcinogens in NTP’s 9^th^ Report on Carcinogens (2001). Hydrazine is classified in EPA cancer Group B2 (probable human carcinogen) (IRIS 2001). EPA calculated for hydrazine an oral slope factor of 3.0 (mg/kg-day)^−1^ based on hepatomas in male mice treated by gavage, and an inhalation unit risk of 4.9×10^−3^ (μg/m^3^)^−1^ based on nasal cavity adenomas or adenocarcinomas in male rats (IRIS 2001).

## B.5 References

ATSDR. 1997a. Toxicological profile for hydrazines. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
EPA. 1997. Health effects assessment summary tables. Washington, DC: U.S. Environmental Protection Agency, Solid Waste and Emergency Response, EPA-540-R-97–036; PB97–92119.
IARC. 2001. Overall evaluations of carcinogenicity to humans. Lyons, France: International Agency for Research on Cancer. http://193.51.164.11/monoeval/crthall.html. December 13, 2001.
IRIS. 2001. Integrated Risk Information System. http://www.epa.gov/iris/. September 04, 2001.
NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.