# Appendix A Background Information for Jet Fuels

Jet fuels are complex mixtures of hydrocarbons produced by distillation of petroleum crude oil. Most jet fuels (e.g., JP-5, JP-7, JP-8) are middle distillates similar in composition to kerosene and containing primarily C_9_–C_16_ hydrocarbons (approximately 80% aliphatic and 20% aromatic). JP-4 is a “wide-cut” fuel that is a blend of kerosene with lower boiling naphtha streams, like those used to produce gasoline, and therefore, containing a greater range of hydrocarbons (C_4_–C_16_). Although the composition of JP-4 is notably different from the kerosene-type fuels, and minor differences exist also among the latter, obvious differences in toxicity have not been reported in the published literature. Therefore, these fuels are discussed together below.

## A.1 Toxicokinetics

Absorption following inhalation exposure to jet fuels and related substances can be inferred from the occurrence of systemic health effects in humans and research animals exposed by inhalation (ATSDR 1995a, 1995b, 1998). In addition, studies have demonstrated that a mixture of aliphatic hydrocarbons mostly in the C_10_–C_12_ range (white spirit) was readily absorbed through the lungs in humans, that individual alkanes and cycloalkanes in the range of C_6_–C_10_ were absorbed in rats exposed by inhalation, and that isopropylbenzene (cumene), which is representative of the aromatic C_9_–C_16_ fraction, had a pulmonary retention percentage of approximately 50% in human volunteers (ATSDR 1999). Data on oral absorption of jet fuels and related substances are limited, but suggest that these substances are absorbed from the gastrointestinal tract (ATSDR 1995a, 1995b, 1998). Gastrointestinal absorption of aliphatic hydrocarbons is inversely proportional to length of the carbon chain; absorption is approximately 60% for C_14_ hydrocarbons (ATSDR 1999). Aromatic hydrocarbons in this size range are well absorbed from the gut when administered at low doses: 80–90% of ingested 2-methylnaphthalene and isopropylbenzene was recovered in the urine (ATSDR 1999). Oral exposure can also result in the fuels being aspirated into the lungs, leading to respiratory effects (ATSDR 1995a, 1998). Systemic health effects have been reported following dermal application of JP-5, kerosene, and several aromatic compounds of the appropriate size (isopropylbenzene, naphthalene, monomethylnaphthalenes), indicating that these substances are absorbed through the skin (ATSDR 1995a, 1995b, 1998, 1999). McDougal et al. (2000) studied skin absorption and penetration of JP-8 and its components in an in vitro system using rat skin. These researchers found that total flux of hydrocarbons across the skin was a relatively slow 20.3 μg/cm^2^/hour. A total of 13 individual components were found to penetrate the skin, with fluxes ranging from a high of 51.5 μg/cm^2^/hour for diethylene glycol monomethyl ether (an additive) to 0.334 μg/cm^2^/hour for tridecane. In general, aromatic compounds penetrated skin more rapidly than aliphatics. Six compounds, all aliphatic, were absorbed into the skin; concentrations ranged from 0.055 μg/g skin (tetradecane) to 0.266 μg/g skin (undecane) after 3.5 hours.

Limited data suggest that jet fuels and related substances are widely distributed throughout the body after being absorbed (ATSDR 1995a, 1995b, 1998, 1999). Studies with white spirit (C_10_–C_12_ aliphatic) and individual aliphatic hydrocarbons in the C_6_–C_10_ range showed that these chemicals can accumulate in fat (ATSDR 1999). Following gastrointestinal absorption, the larger molecular weight aliphatics are transported primarily by the lymphatic system, while the smaller ones are transported by both the lymph and the blood. There is no information available on metabolism of jet fuels and related substances (ATSDR 1995a, 1995b, 1998), but data on C_9_–C_16_ hydrocarbons suggest that metabolism of aliphatics in this range (primarily cytochrome P-450 mediated oxidation to fatty acids and alcohols) is slow, while the aromatics are metabolized faster (oxidation of alkyl site and/or ring, sometimes with formation of reactive intermediates, and conjugation with glutathione, glucuronic acid, or glycine) (ATSDR 1999). Data on elimination of jet fuels and related substances are not available (ATSDR 1995a, 1995b, 1998). It is noteworthy, however, that white spirit (C_10_–C_12_ aliphatic) is only slowly eliminated from the fat, while aromatics in this size range are excreted rapidly as metabolites in the urine (ATSDR 1999).

## A.2 Health Effects

Jet fuels can produce central nervous system impairment in humans by all routes of exposure, characterized by effects such as fatigue, coordination and concentration difficulties, headache, intoxication, anorexia, depressed mood, lack of initiative, dizziness, sleep disturbances, changes in posture, and reduced sensorimotor speed (ATSDR 1995b, 1998, 1999). Unconsciousness, coma, and convulsions have been observed after ingestion of kerosene by children. Similar symptoms of central nervous system depression have been observed in animal studies. Jet fuels and related substances can also produce respiratory, gastrointestinal, dermal, and ocular irritation in humans and animals (ATSDR 1995b, 1998, 1999). Respiratory effects may occur as a result of inhalation of jet fuel vapor, but in humans, have been more commonly and severely associated with aspiration into the lungs following oral exposure. Gastrointestinal effects have been noted after both inhalation and oral exposure. Dermal effects are usually a result of direct skin contact with the fuel, but have also been reported after oral exposure. Eye irritation has been reported as a consequence of exposure to jet fuel vapor in humans, although studies of direct ocular contact in animals have been negative.

Animal studies have also identified the liver, kidney, and immune system as targets for jet fuel toxicity. The liver is a sensitive and commonly affected endpoint in animal studies. MRLs for JP-4, JP-5, JP-7, and JP-8 are all based on liver effects (ATSDR 1995b, 1998). Observed effects in the liver include degenerative fatty change, hepatocellular necrosis, and hepatic inflammation. Hepatotoxicity was also indicated by increases in serum enzyme activities. In the kidney, animal studies have shown that jet fuels produce hyaline droplet nephropathy, which is unique to male rats and not predictive of renal effects in humans. Jet fuels and kerosine have also been found to produce immunosuppression (suppressed hypersensitivity reactions to antigens, suppressed ability of splenic T-cells to respond to mitogens, decreased number of viable immune cells, decreased immune organ weights) by inhalation and dermal exposure, while also being weak dermal sensitizers themselves (ATSDR 1998; Stoica et al. 2001; Ullrich 1999). A developmental toxicity study of JP-8 found decreased fetal body weight associated with oral exposure during gestation, but only at doses that also produced significant decreases in maternal weight gain (ATSDR 1998). Data regarding reproductive toxicity are not available. Genotoxicity testing has been fairly extensive, and the results have been overwhelmingly negative (ATSDR 1995b, 1998). Skin painting studies with jet fuels and kerosene have produced evidence suggesting that chronic dermal application of these substances can produce skin tumors (ATSDR 1995b, 1998, 1999; Rosenthal et al. 2001). Dermal tumorigenesis or tumor promotion by these substances may be related to their ability to produce skin irritation and dermal cell toxicity (Rosenthal et al. 2001). Data regarding internal cancers in humans and animals are equivocal.

## A.3 Mechanisms of Action

Central nervous system depression, as observed for jet fuels, is an effect common to many organic solvents. It is generally thought to occur when the lipophilic parent compound partitions into the nerve cell membranes and disrupts function of membrane proteins by disturbing their lipid environment or by directly altering protein conformation (ATSDR 1999). Oxidative metabolism of the parent compounds reduces their lipophilicity and counteracts their central nervous system depressive effects. The hydrocarbon parent compounds in jet fuels are also thought to be responsible for the respiratory irritation and pneumonitis that can result from inhalation or aspiration of these fuels. It has been hypothesized that the parent hydrocarbons interact with nerve cell membranes, resulting in bronchoconstriction, and dissolve into membranes of the lung parenchyma, resulting in hemorrhagic exudation of proteins, cells, and fibrin into the alveoli (ATSDR 1999). In vitro experiments have shown that JP-8 induces apoptotic cell death in rat lung epithelial cells, apparently by damaging mitochondria in the cells (Stoica et al. 2001). JP-8 also induced apoptosis in immune system cells (U-937 human monocytic cells, Jurkat T-cell leukemia cells, primary mouse thymocytes) in vitro (Stoica et al. 2001). In contrast, JP-8 produced necrotic cell death in primary and immortalized human keratinocytes and primary mouse skin fibroblasts in culture and when applied topically to immortalized human keratinocytes grafted onto nude mice (Rosenthal et al. 2001). While the central nervous system and irritant effects of jet fuels are apparently due to the parent hydrocarbons, effects on the liver and kidney are probably due to formation of reactive intermediates and metabolites during oxidative metabolism, and to subsequent binding of these reactive species to cellular macromolecules.

## A.4 Health Guidelines

ATSDR (1995a) derived an intermediate-duration inhalation MRL of 9 mg/m^3^ for JP-4 based on a lowest-observed-adverse-effect level (LOAEL) of 500 mg/m^3^ for hepatotoxicity (hepatocellular fatty change) in female mice in a 90-day continuous exposure study, a human equivalent dose conversion factor of 5.7, and an uncertainty factor of 300 (10 for the use of a LOAEL, 3 for interspecies extrapolation, and 10 for human variability). ATSDR (1995b) also derived a chronic inhalation MRL of 0.3 mg/m^3^ for JP-7 based on a LOAEL of 150 mg/m^3^ for hepatic inflammation in female mice exposed intermittently for 1 year (LOAEL_ADJ_=26.8 mg/m^3^), a human equivalent dose conversion factor of 3.3 (0.36 m^3^/day/0.38 kg × 70 kg/20 m^3^/day), and an uncertainty factor of 300 (10 for the use of a LOAEL, 3 for interspecies extrapolation, and 10 for human variability). ATSDR (1998) derived an intermediate inhalation MRL of 3 mg/m^3^ for JP-5 and JP-8 based on a LOAEL of 150 mg/m^3^ for hepatocellular fatty change in mice exposed to JP-5 continuously for 90 days (LOAEL_HEC_=150 mg/m^3^ × 0.04 m^3^/day/0.0246 kg × 70 kg/20 m^3^/day=854 mg/m^3^), and an uncertainty factor of 300 (10 for the use of a LOAEL, 3 for interspecies extrapolation, and 10 for human variability). ATSDR (1995a) derived an intermediate inhalation MRL for kerosene of 0.01 mg/m^3^ based on decreased blood glucose levels (thought to be indicative of hepatic effects) in male rats intermittently exposed to 58 mg/m^3^ for 14 weeks (LOAEL_ADJ_=12.4 mg/m^3^) and an uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for interspecies extrapolation, and 10 for human variability). ATSDR (1999) noted that the MRL for kerosene involves greater uncertainty regarding toxicological significance of the observed effect (decreased blood glucose) than the MRLs for JP-5, JP-8, and JP-7 (liver pathology), and chose the latter MRLs (and not the kerosene MRL) to be the appropriate surrogate values for the assessment of health effects due to exposure to the kerosene-like fraction (C_8_–C_16_ aliphatics) of TPH (total petroleum hydrocarbons). Data on jet fuels and related substances were inadequate to support inhalation MRLs of other durations or oral MRLs. EPA does not list assessments for jet fuels or related substances on the Integrated Risk Information System (IRIS 2001) or in the Health Effects Assessment Summary Tables (HEAST) (EPA 1997). The International Agency for Research on Cancer (IARC 2001) placed jet fuels in cancer weight-of-evidence Group 3 (not classifiable as to human carcinogenicity). Jet fuels are not listed in National Toxicology Program’s (NTP) 9^th^ Report on Carcinogens (2001).

## A.5 References

ATSDR. 1995a. Toxicological profile for fuel oils. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1995b. Toxicological profile for jet fuels (JP4 and JP7). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1998. Toxicological profile for JP-5 and JP-8. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1999. Toxicological profile for total petroleum hydrocarbons (TPH). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
EPA. 1997. Health effects assessment summary tables. Washington, DC: U.S. Environmental Protection Agency, Solid Waste and Emergency Response. EPA-540-R-97–036. PB97–92119.
IARC. 2001. Overall evaluations of carcinogenicity to humans. Lyons, France: International Agency for Research on Cancer. http://193.51.164.11/monoeval/crthall.html. December 13, 2001.
IRIS. 2001. Integrated Risk Information System. http://www.epa.gov/iris/. September 04, 2001.
McDougal JN, Pollard DL, Weisman W, 2000. Assessment of skin absorption and penetration of JP-8 jet fuel and its components. Toxicol Sci 55:247–255.10828255
NTP. 2001. 9^th^ Report on carcinogens. Washington, DC: U.S. Department of Health and Human Services. National Toxicology Program. U.S. Public Health Service.
Rosenthal DS, Simbulan-Rosenthal CG, Liu WF, 2001. Mechanisms of JP-8-jet fuel toxicity. 1. Induction of necrosis in skin fibroblasts and keratinocytes and modulation of levels of Bcl-2 family members. Toxicol Appl Pharmacol 171:107–116.11222086
Stocia BA, Boulares AH, Rosenthal DS, 2001. Mechanisms of JP-8 jet fuel. 1. Induction of apoptosis in rat lung epithelial cells. Toxicol Appl Pharmacol 171:94–106.11222085
Ullrich SE. 1999. Dermal application of JP-8 jet fuel induces immune suppression. Toxicol Sci 52:61–67.