# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
As: arsenic
As_2_O_3_: arsenic trioxide
ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
BrdU: bromo-deoxyuridine
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
CI: confidence interval
DNA: deoxyribonucleic acid
DMA: dimethylarsinic acid
DT: Division of Toxicology
EDTA: ethylenediaminetetraacetic acid
EPA: Environmental Protection Agency
FQPA: Food Quality Protection Act
gastro: gastrointestinal
GST-P: glutathione S-transferase-placental
HEAST: Health Effects Assessment Summary Tables
IARC: International Agency for Research on Cancer
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LOAEL: lowest-observed-adverse-effect level
m^3^: cubic meter
MeV: millions of electron volts
mg: milligram
MMA: monomethylarsonic acid
MRL: Minimal Risk Level
neuro: neurological
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic/pharmacodynamic
pCi: picocurie
ppm: parts per million
RfC: Reference Concentration
RfD: Reference Dose
RR: relative risk
Sr: strontium
SrCl_2_: strontium chloride
t_1/2_: half-life
TPH: total petroleum hydrocarbons
TTD: target-organ toxicity dose
TUNEL: TdT-mediated dUTP digoxigenin nick end labeling
μg: microgram
μM: micromolar
U.S.: United States
WOE: weight-of-evidence
Y: Yttrium
Zn: Zinc
Zr: Zirconium
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to