# CHAPTER 8 REFERENCES

ACC. 2019. The economic benefits of ethylene oxide and the potential cost of deselection. American Chemistry Council. https://www.americanchemistry.com/EO/Ethylene-Oxide-and-the-Potential-Cost-of-Deselection.pdf. February 27, 2020.
Adkins B, Van Stee EW, Simmons JE, . 1986. Oncogenic response of strain A/J mice to inhaled chemicals. J Toxicol Environ Health 17(2–3):311–322. 10.1080/15287398609530825.3083111
Agurell E, Cederberg H, Ehrenberg L, . 1991. Genotoxic effects of ethylene oxide and propylene oxide: a comparative study. Mutat Res 250(1–2):229–237. 10.1016/0027-5107(91)90180-v.1944340
Alexander M. 1977. Transformation of hydrocarbons. In: Introduction to soil microbiology. 2nd ed. New York, NY: John Wiley & Sons, 207.
Alomar A, Camarasa JM, Noguera J, . 1981. Ethylene oxide dermatitis. Contact Dermatitis 7:205–207.7326926
Alwis KU, Blount BC, Britt AS, . 2012. Simultaneous analysis of 28 urinary VOC metabolites using ultra high performance liquid chromatography coupled with electrospray ionization tandem mass spectrometry (UPLC-ESI/MSMS). Anal Chim Acta 750:152–160. 10.1016/j.aca.2012.04.009.23062436
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
Anbar M, Neta P. 1967. A compilation of specific biomolecular rate constants for the reactions of hydrated electrons, hydrogen atoms and hydroxyl radicals with inorganic and organic compounds in aqueous solution. Int J Appl Radiat Isot 18:493–523.
Angerer J, Bader M, Kramer A. 1998. Ambient and biochemical effect monitoring of workers exposed to ethylene oxide. Int Arch Occup Environ Health 71(1):14–18. 10.1007/s004200050244.9523244
Appelgren L, Eneroth G, Grant C. 1977. Studies on ethylene oxide: Whole body autoradiography and dominant lethal test in mice. Arch Toxicol 18:315–317.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2018. Letter health consultation: “Evaluation of potential health impacts from ethylene oxide emissions” Sterigenics International, Inc., Willowbrook, Illinois. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/sterigenic/Sterigenics_International_Inc-508.pdf. March 21, 2019.
ATSDR. 2019. Ethylene oxide. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bastlova T, Andersson B, Lambert B, . 1993. Molecular analysis of ethylene oxide-induced mutations at the HPRT locus in human diploid fibroblasts. Mutat Res 287(2):283–292. 10.1016/0027-5107(93)90021-7.7685488
Belen B, Polat M. 2015. Type I allergic hypersensitivity reactions due to ethylene oxide sterilised leucocyte filters in patients with thalassaemia: report of four cases. BMJ Case Rep 2015:27. 10.1136/bcr-2014-208490.
Bennett DH, Margni MD, McKone TE, . 2002. Intake fraction for multimedia pollutants: a tool for life cycle analysis and comparative risk assessment. Risk Anal 22(5):905–918. 10.1111/1539-6924.00260.12442988
Benson LO, Teta MJ. 1993. Mortality due to pancreatic and lymphopoietic cancers in chlorohydrin production workers. Br J Ind Med 50(8):710–716. 10.1136/oem.50.8.710.8398857
Bird MJ. 1952. Chemical production of mutations in Drosophila: Comparison of techniques. J Genet 50:480–485.
Bisanti L, Maggini M, Raschetti R, . 1993. Cancer mortality in ethylene oxide workers. Br J Ind Med 50(4):317–324. 10.1136/oem.50.4.317.8494771
Blackwood JD, Erskine EB. 1938. Carboxide poisoning. U S Nav Med Bull 36:44–45.
Bogan DJ, Hand CW. 1978. Absolute rate constant, kinetic isotope effect, and mechanism of the reaction of ethylene oxide with oxygen (3P) atoms. J Phys Chem 82:2037–2073.
Bono R, Vincenti M, Meineri V, . 1999. Formation of N-(2-hydroxyethyl)valine due to exposure to ethylene oxide via tobacco smoke: A risk factor for onset of cancer. Environ Res 81(1):62–71. 10.1006/enrs.1998.3937.10361027
Bono R, Vincenti M, Saglia U, . 2002. Tobacco smoke and formation of N-(2-hydroxyethyl)valine in human hemoglobin. Arch Environ Health 57(5):416–421. 10.1080/00039890209601430.12641182
Bono R, Vincenti M, Schiliro T, . 2005. Cotinine and N-(2-hydroxyethyl)valine as markers of passive exposure to tobacco smoke in children. J Expo Anal Environ Epidemiol 15(1):66–73. 10.1038/sj.jea.7500344.15026775
Boogaard PJ. 2002. Use of haemoglobin adducts in exposure monitoring and risk assessment. J Chromatogr B Analyt Technol Biomed Life Sci 778(1–2):309–322. 10.1016/s0378-4347(01)00445-5.
Boogaard PJ, Rocchi PS, van Sittert NJ. 1999. Biomonitoring of exposure to ethylene oxide and propylene oxide by determination of hemoglobin adducts: correlations between airborne exposure and adduct levels. Int Arch Occup Environ Health 72(3):142–150. 10.1007/s004200050353.10392561
Brashear A, Unverzagt FW, Farber MO, . 1996. Ethylene oxide neurotoxicity: a cluster of 12 nurses with peripheral and central nervous system toxicity. Neurology 46(4):992–998. 10.1212/wnl.46.4.992.8780078
Brown AM, Bruch C, Jacobson E, . 1979. Increased mutation frequency due to ethylene oxide absorbed to plastics. In Vitro 15:220–221.
Brown CD, Wong BA, Fennell TR. 1996. In vivo and in vitro kinetics of ethylene oxide metabolism in rats and mice. Toxicol Appl Pharmacol 136(1):8–19. 10.1006/taap.1996.0002.8560484
Brown CD, Asgharian B, Turner MJ, . 1998. Ethylene oxide dosimetry in the mouse. Toxicol Appl Pharmacol 148(2):215–221. 10.1006/taap.1997.8349.9473528
Brugnone F, Perbellini L, Faccini G, . 1985. Concentration of ethylene oxide in the alveolar air of occupationally exposed workers. Am J Ind Med 8(1):67–72. 10.1002/ajim.4700080109.4025340
Brugnone F, Perbellini L, Faccini GB, . 1986. Ethylene oxide exposure. Biological monitoring by analysis of alveolar air and blood. Int Arch Occup Environ Health 58(2):105–112. 10.1007/BF00380761.3744564
CARB. 1992. Assessment of ethylene oxide concentrations and emissions from sterilization and fumigation processes. Sacramento, CA: California Air Resources Board. https://ww3.arb.ca.gov/research/apr/past/a832-125.pdf. June 26, 2019.
Caroli UM, Berner D, Volz T, . 2005. Delayed-type hypersensitivity dermatitis to ethylene oxide. Contact Dermatitis 53(5):303–304. 10.1111/j.0105-1873.2005.0654e.x.16283913
CDC. 2022. Updated ethylene oxide hemoglobin adduct data tables published. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/whats_new_060622_1.html. July 11, 2022.
CDPHE. 2018. Ethylene oxide/Terumo BCT air sampling study pre- and post-control air monitoring report. Colorado Department of Public Health and Environment. https://www.colorado.gov/pacific/cdphe/ethylene-oxide. October 25, 2019.
Celanese Chem Co. 1972. Primary skin irritation tests with eighteen materials in albino rabbits. Celanese Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0206028. EPA Document No. 878212151.
Cherrie JW, Sewell C, Ritchie P, . 2001. Retrospective collection of exposure data from industry: results from a feasibility study in the United Kingdom. Appl Occup Environ Hyg 16(2):144–148. 10.1080/104732201460235.11217701
Chien YC, Liu HH, Lin YC, . 2007. Ethylene oxide sterilization in the medical-supply manufacturing industry: assessment and control of worker exposure. J Biomed Mater Res B Appl Biomater 83(2):527–537. 10.1002/jbm.b.30825.17471516
Chien YC, Su PC, Lee L, . 2009. Emission characteristics of plastic syringes sterilized with ethylene oxide-A controlled study. J Biomed Mater Res 91B(2):579–586. 10.1002/jbm.b.31432.
Clare MG, Dean BJ, de Jong G, . 1985. Chromosome analysis of lymphocytes from workers at an ethylene oxide plant. Mutat Res 156:109–116.4000173
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Coggon D, Harris EC, Poole J, . 2004. Mortality of workers exposed to ethylene oxide: extended follow up of a British cohort. Occup Environ Med 61(4):358–362. 10.1136/oem.2003.008268.15031395
Conway RA, Waggy GT, Spiegel MH, . 1983. Environmental fate and effects of ethylene oxide. Environ Sci Technol 17(2):107–112. 10.1021/es00108a009.22295963
Crystal HA, Schaumburg HH, Grober E, . 1988. Cognitive impairment and sensory loss associated with chronic low-level ethylene oxide exposure. Neurology 38(4):567–569. 10.1212/wnl.38.4.567.3352912
Csanady GA, Denk B, Putz C, . 2000. A physiological toxicokinetic model for exogenous and endogenous ethylene and ethylene oxide in rat, mouse, and human: formation of 2-hydroxyethyl adducts with hemoglobin and DNA. Toxicol Appl Pharmacol 165(1):1–26. 10.1006/taap.2000.8918.10814549
Cumming RB, Sega GA, Horton CY, . 1981. Degree of alkylation of DNA in various tissues of the mouse following inhalation exposure to ethylene oxide. Environ Mutagen 3:343.
Cummins K, Burroughs GE, Tremblay J. 1993. A field comparison of methods for monitoring ethylene oxide concentration. Appl Occup Environ Hyg 8(5):463–471. 10.1080/1047322X.1993.10388142.
Dagregorio G, Guillet G. 2004. Allergic suture material contact dermatitis induced by ethylene oxide. Allergy 59(11):1239. 10.1111/j.1398-9995.2004.00598.x.
Dauvois C, Chaigneau M, Le Moan G. 1982. [Sterilization of dressings by ethylene oxide. I. Physisorption]. Ann Pharm Fr 40(2):125–132. (French)7137808
De Bont JA, Albers RA. 1976. Microbial metabolism of ethylene. Antonie Van Leeuwenhoek 42(1–2):73–80. 10.1007/BF00399450.8000
De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2(4):283–298. 10.1093/carcin/2.4.283.7023727
de Serres FJ, Brockman HE. 1995. Ethylene oxide: induction of specific-locus mutations in the ad-3 region of heterokaryon 12 of Neurospora crassa and implications for genetic risk assessment of human exposure in the workplace. Mutat Res 328(1):31–47. 10.1016/0027-5107(94)00194-a.7898502
Deschamps D, Rosenberg N, Soler P, . 1992. Persistent asthma after accidental exposure to ethylene oxide. Br J Ind Med 49(7):523–525. 10.1136/oem.49.7.523.1637714
Dickson WM, Patterson EB, Stern JR, . 1954. The effect of terramycin or fish solubles, or both, on the growth, adrenal glands and gonads of the rat. J Nutr 54(4):631–641. 10.1093/jn/54.4.631.13222186
Dietz DD, Abdo KM, Haseman JK, . 1991. Comparative toxicity and carcinogenicity studies of tetracycline and oxytetracycline in rats and mice. Fundam Appl Toxicol 17(2):335–346. 10.1016/0272-0590(91)90223-q.1765221
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
Donner EM, Wong BA, James RA, . 2010. Reciprocal translocations in somatic and germ cells of mice chronically exposed by inhalation to ethylene oxide: implications for risk assessment. Mutagenesis 25(1):49–55. 10.1093/mutage/gep042.19884119
Dretchen KL, Balter NJ, Schwartz SL, . 1992. Cognitive dysfunction in a patient with long-term occupational exposure to ethylene oxide. Role of ethylene oxide as a causal factor. J Occup Med 34(11):1106–1113. 10.1097/00043764-199211000-00014.1432302
Dunkelberg H. 1982. Carcinogenicity of ethylene oxide and 1,2-propylene oxide upon intragastric administration to rats. Br J Cancer 46(6):924–933. 10.1038/bjc.1982.303.7150486
Eckert E, Schmid K, Schaller B, . 2011. Mercapturic acids as metabolites of alkylating substances in urine samples of German inhabitants. Int J Hyg Environ Health 214(3):196–204. 10.1016/j.ijheh.2011.03.001.21459667
Ehrenberg L, Hiesche KD, Osterman-Golkar S, . 1974. Evaluation of genetic risks of alkylating agents: tissue doses in the mouse from air contaminated with ethylene oxide. Mutat Res 24(2):83–103. 10.1016/0027-5107(74)90123-7.4851925
Embree JW, Lyon JP, Hine CH. 1977. The mutagenic potential of ethylene oxide using the dominantlethal assay in rats. Toxicol Appl Pharmacol 40:261–267.877959
EPA. 1980. Investigation of selected potential environmental contaminants: Epoxides. U.S. Environmental Protection Agency. EPA5601180005. PB80183197. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80183197.xhtml. March 21, 2019.
EPA. 1984a. Ethylene oxide; response to the interagency testing committee. U.S. Environmental Protection Agency. Fed Regist 49:200–205.
EPA. 1984b. Health and environmental effects profile for oxirane. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600X84222. PB88162318. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88162318.xhtml. March 21, 2019.
EPA. 1984c. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Fed Regist 49(218):44718–44721.
EPA. 1985. Health assessment document for ethylene oxide. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600884009F. PB86102597. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB86102597.xhtml. March 21, 2019.
EPA. 1989. Land disposal restrictions for second third scheduled wastes. U.S. Environmental Protection Agency. Fed Regist 54:1056–1119.
EPA. 1994. Data evaluation report: Ethylene oxide (EtO): Range-finding/developmental studies in rats (MRID #427977-01 and -02). D192811. Two generation reproduction study in rats (MRID #427881-01). D192453 (Previous 189547). Washington, DC: U.S. Environmental Protection Agency.
EPA. 2004. Ethylene oxide commercial sterilization and fumigation operations NESHAP. Implementation document. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA456R97004. PB98103385. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB98103385.xhtml. March 21, 2019.
EPA. 2005a. Data evaluation record: Ethylene oxide/042301 [OPPTS 870-6200a (S81-8): Study type: Acute inhalation neurotoxicity study in rats. MRID 44256402]. U.S. Environmental Protection Agency.
EPA. 2005b. Data evaluation record: Ethylene oxide/042301 [OPPTS 870-6200a (S81-8): Study type: Subchronic inhalation neurotoxicity study in rats. MRID 44256401 (range-finding study); MRID 44359401 (main-study)]. U.S. Environmental Protection Agency.
EPA. 2005c. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act. U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2006. Report of the food quality protection act (FQPA) tolerance reassessment and risk management decision (TRED) for ethylene oxide. U.S. Environmental Protection Agency. EPA730R06032. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100BIA1.txt. April 22, 2020.
EPA. 2007. Method 8015C. Nonhalogenated organics by gas chromatography. Hazardous waste test methods. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/8015c.pdf. March 21, 2019.
EPA. 2008. Reregistration eligibility decision for ethylene oxide. U.S. Environmental Protection Agency. EPA738R08003. https://archive.epa.gov/pesticides/reregistration/web/pdf/ethylene-oxide-red.pdf. March 20, 2019.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2014. 2012 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/chemical-data-reporting-previously-collected-data. February 28, 2019.
EPA. 2016. Evaluation of the inhalation carcinogenicity of ethylene oxide (CASRN 75-21-8) in support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R16350F. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1025tr.pdf. June 24, 2019.
EPA. 2017a. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. February 28, 2019.
EPA. 2017b. Ethylene oxide: 75-21-8. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-09/documents/ethylene-oxide.pdf. March 20, 2017.
EPA. 2018a. Air toxics - Data analysis: Massachusetts, New Hampshire, Rhode Island. U.S. Environmental Protection Agency. https://www3.epa.gov/ttn/amtic/toxdat.html#data. October 25, 2019.
EPA. 2018b. Technical support document EPA’s 2014 national air toxics assessment. Research Triangle Park, NC: U.S. Environmental Protection Agency. 2014 NATA TSD. https://www.epa.gov/sites/production/files/2018-09/documents/2014_nata_technical_support_document.pdf. March 21, 2019.
EPA. 2018c. Ethylene oxide. [Emission estimates 2014 NATA]. Pollutant specific results. U.S. Environmental Protection Agency. https://www.epa.gov/national-air-toxics-assessment/2014-nata-assessment-results#pollutant. February 26, 2019.
EPA. 2018d. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018e. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. February 11, 2021.
EPA. 2018f. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2019a. Method TO-15A: Determination of volatile organic compounds (VOCs) in air collected in specially prepared canisters and analyzed by gas chromatography/mass spectrometry (GC-MS). U.S. Environmental Protection Agency. EPA457B19005. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100YDPO.txt. August 3, 2020.
EPA. 2019b. Risk assessment report for the Sterigenics facility in Willowbrook, Illinois. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2019-08/documents/risk_assessment_for_sterigenics_willowbrook_il.pdf. October 25, 2019.
EPA. 2020a. 2017 National emissions inventory (NEI) data, April 2020 version. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. August 3, 2020.
EPA. 2020b. Ethylene oxide ambient concentrations at national air toxics trends stations and urban air toxics monitoring program stations. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2019-11/documents/data_summary_stations.pdf. October 19, 2021.
EPA. 2020c. Memorandum: Ethylene oxide (EtO). Draft human health and ecological risk assessment in support of registration review. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2020-11/documents/d458706-eto-final-dra-nov-3-2020.pdf. July 16, 2021.
Estrin WJ, Cavalieri SA, Wald P, . 1987. Evidence of neurologic dysfunction related to long-term ethylene oxide exposure. Arch Neurol 44(12):1283–1286. 10.1001/archneur.1987.00520240057012.3314817
Fahmy OG, Fahmy MJ. 1956. Cytogenetic analysis of the action of carcinogens and tumour inhibitors in Drosophila melanogaster. J Genet 54:146–164.
Fahmy OG, Fahmy MJ. 1970. Gene elimination in carcinogenesis: reinterpretation of the somatic mutation theory. Cancer Res 30(1):195–205.5458960
Farmer PB, Cordero R, Autrup H. 1996. Monitoring human exposure to 2-hydroxyethylating carcinogens. Environ Health Perspect 104 Suppl 3(Suppl 3):449–452. 10.1289/ehp.96104s3449.8781362
Farooqi Z, Tornqvist M, Ehrenberg L, . 1993. Genotoxic effects of ethylene oxide and propylene oxide in mouse bone marrow cells. Mutat Res 288(2):223–228. 10.1016/0027-5107(93)90088-w.7688081
FDA. 2021. Ethylene oxide-NLFG. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=ETHYLENEOXIDENLFG. February 17, 2021.
Fennell TR, Brown CD. 2001. A physiologically based pharmacokinetic model for ethylene oxide in mouse, rat, and human. Toxicol Appl Pharmacol 173(3):161–175. 10.1006/taap.2001.9184.11437638
Fennell TR, MacNeela JP, Morris RW, . 2000. Hemoglobin adducts from acrylonitrile and ethylene oxide in cigarette smokers: effects of glutathione S-transferase T1-null and M1-null genotypes. Cancer Epidemiol Biomarkers Prev 9(7):705–712.10919741
Fennell TR, Snyder RW, Parkinson C, . 2004. The effect of ethylene exposure on ethylene oxide in blood and on hepatic cytochrome P450 in Fischer rats. Toxicol Sci 81(1):7–13. 10.1093/toxsci/kfh170.15141094
Filser JG, Bolt HM. 1984. Inhalation pharmacokinetics based on gas uptake studies. VI. Comparative evaluation of ethylene oxide and butadiene monoxide as exhaled reactive metabolites of ethylene and 1,3-butadiene in rats. Arch Toxicol 55:219–223.6517697
Filser JG, Klein D. 2018a. A physiologically based toxicokinetic model for inhaled ethylene and ethylene oxide in mouse, rat, and human. Toxicol Lett 286:54–79. 10.1016/j.toxlet.2017.07.896.28774830
Filser JG, Klein D. 2018b. Appendix B. Supplementary data: A physiologically based toxicokinetic model for inhaled ethylene and ethylene oxide in mouse, rat, and human. Toxicol Lett 286:Appendix B. https://ars.els-cdn.com/content/image/1-s2.0-S0378427417311426-mmc1.docx. March 21, 2019.
Filser JG, Denk B, Törnqvist M, . 1992. Pharmacokinetics of ethylene in man; body burden with ethylene oxide and hydroxyethylation of hemoglobin due to endogenous and environmental ethylene. Arch Toxicol 66(3):157–163.1303633
Filser JG, Kessler W, Artati A, . 2013. Ethylene oxide in blood of ethylene-exposed B6C3F1 mice, Fischer 344 rats, and humans. Toxicol Sci 136(2):344–358. 10.1093/toxsci/kft218.24068676
Filser JG, Artati A, Li Q, . 2015. Novel and existing data for a future physiological toxicokinetic model of ethylene and its metabolite ethylene oxide in mouse, rat, and human. Chem Biol Interact 241:76–86. 10.1016/j.cbi.2015.04.002.25868680
Finelli PF, Morgan TF, Yaar I, . 1983. Ethylene oxide-induced polyneuropathy. A clinical and electrophysiologic study. Arch Neurol 40(7):419–421. 10.1001/archneur.1983.04050070049010.6305316
Florack EI, Zielhuis GA. 1990. Occupational ethylene oxide exposure and reproduction. Int Arch Occup Environ Health 62(4):273–277. 10.1007/BF00640833.2199374
Fritz B, Lorenz K, Steinert W, . 1982. Laboratory kinetic investigations of the tropospheric oxidation of selected industrial emissions. In: Versino B, Ott H, eds. Physico-chemical behaviour of atmospheric pollutants: Proceedings of the second European Symposium held in Varese, Italy, September–October 1981. Netherlands: Springer, 192–202.
Fuchs J, Wullenweber U, Hengstler JG, . 1994. Genotoxic risk for humans due to work place exposure to ethylene oxide: remarkable individual differences in susceptibility. Arch Toxicol 68(6):343–348. 10.1007/s002040050080.8092925
Fujishiro K, Mori K, Inoue N. 1990. Chronic inhalation effects of ethylene oxide on porphyrin-heme metabolism. Toxicology 61(1):1–11. 10.1016/0300-483x(90)90002-x.2315947
Galloway SM, Berry PK, Nichols WW, . 1986. Chromosome aberrations in individuals occupationally exposed to ethylene oxide, and in a large control population. Mutat Res 170(1–2):55–74. 10.1016/0165-1218(86)90082-0.3960044
Gardner MJ, Coggon D, Pannett B, . 1989. Workers exposed to ethylene oxide: a follow up study. Br J Ind Med 46(12):860–865. 10.1136/oem.46.12.860.2611160
Garman RH, Snellings WM, Maronpot RR. 1985. Brain tumors in F-344 rats associated with chronic inhalation exposure to ethylene oxide. Neurotoxicology 6(1):117–137.
Garman RH, Snellings WM, Maronpot RR. 1986. Frequency, size and location of brain tumours in F344 rats chronically exposed to ethylene oxide. Food Chem Toxicol 24(2):145–153. 10.1016/0278-6915(86)90349-2.3957162
Garry VF, Hozier J, Jacobs D, . 1979. Ethylene oxide: evidence of human chromosomal effects. Environ Mutagen 1(4):375–382. 10.1002/em.2860010410.553808
Garry VF, Opp CW, Wiencke JK, . 1982. Ethylene oxide induced sister chromatid exchange in human lymphocytes using a membrane dosimetry system. Pharmacology 25(4):214–221. 10.1159/000137745.7146087
Generoso WM, Cain KT, Krishna M, . 1980. Heritable translocation and dominant-lethal mutation induction with ethylene oxide in mice. Mutat Res 73(1):133–142. 10.1016/0027-5107(80)90142-6.7254215
Generoso WM, Cumming RB, Bandy JA, . 1983. Increased dominant-lethal effects due to prolonged exposure of mice to inhaled ethylene oxide. Mutat Res 119:377–379.6828073
Generoso WM, Cain KT, Hughes LA, . 1986. Ethylene oxide dose and dose-rate effects in the mouse dominant-lethal test. Environ Mutagen 8(1):1–7. 10.1002/em.2860080102.
Generoso WM, Cain KT, Cornett CV, . 1990. Concentration-response curves for ethylene-oxide-induced heritable translocations and dominant lethal mutations. Environ Mol Mutagen 16(2):126–131. 10.1002/em.2850160209.2209562
Georgia EPD. 2021. Ethylene oxide data study. Georgia Environmental Protection Division.
Godderis L, Aka P, Mateuca R, . 2006. Dose-dependent influence of genetic polymorphisms on DNA damage induced by styrene oxide, ethylene oxide and gamma-radiation. Toxicology 219(1–3):220–229. 10.1016/j.tox.2005.11.021.16386346
Greenberg HL, Ott MG, Shore RE. 1990. Men assigned to ethylene oxide production or other ethylene oxide related chemical manufacturing: a mortality study. Br J Ind Med 47(4):221–230. 10.1136/oem.47.4.221.2337530
Gresie-Brusin DF, Kielkowski D, Baker A, . 2007. Occupational exposure to ethylene oxide during pregnancy and association with adverse reproductive outcomes. Int Arch Occup Environ Health 80(7):559–565. 10.1007/s00420-006-0163-y.17165063
Gross JA, Haas ML, Swift TR. 1979. Ethylene oxide neurotoxicity: report of four cases and review of the literature. Neurology 29(7):978–983. 10.1212/wnl.29.7.978.224346
Hagmar L, Welinder H, Linden K, . 1991. An epidemiological study of cancer risk among workers exposed to ethylene oxide using hemoglobin adducts to validate environmental exposure assessments. Int Arch Occup Environ Health 63(4):271–277. 10.1007/BF00386377.1743769
Hagmar L, Mikoczy Z, Welinder H. 1995. Cancer incidence in Swedish sterilant workers exposed to ethylene oxide. Occup Environ Med 52(3):154–156. 10.1136/oem.52.3.154.7735385
Hallier E, Langhof T, Dannappel D, . 1993. Polymorphism of glutathione conjugation of methyl bromide, ethylene oxide and dichloromethane in human blood: influence on the induction of sister chromatid exchanges (SCE) in lymphocytes. Arch Toxicol 67(3):173–178. 10.1007/BF01973304.8494496
Hanifin JM. 1971. Ethylene oxide dermatitis [Letter]. J Am Med Assoc 217:213.
Hansch C, Leo A. 1979. Appendix II. In: Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley & Sons, Inc., 176.
Hansen JP, Allen J, Brock K, . 1984. Normal sister chromatid exchange levels in hospital sterilization employees exposed to ethylene oxide. J Occup Med 26(1):29–32. 10.1097/00043764-198401000-00007.6694005
Hatch GG, Conklin PM, Christensen CC, . 1986. Mutation and enhanced virus transformation of cultured hamster cells by exposure to gaseous ethylene oxide. Environ Mutagen 8(1):67–76. 10.1002/em.2860080107.3943498
Haufroid V, Merz B, Hofmann A, . 2007. Exposure to ethylene oxide in hospitals: biological monitoring and influence of glutathione S-transferase and epoxide hydrolase polymorphisms. Cancer Epidemiol Biomarkers Prev 16(4):796–802. 10.1158/1055-9965.EPI-06-0915.17416773
Hemminki K, Mutanen P, Saloniemi I, . 1982. Spontaneous abortions in hospital staff engaged in sterilising instruments with chemical agents. Br Med J (Clin Res Ed) 285(6353):1461–1463. 10.1136/bmj.285.6353.1461.
Hengstler JG, Fuchs J, Tanner B, . 1997. Analysis of DNA single-strand breaks in human venous blood: a technique which does not require isolation of white blood cells. Environ Mol Mutagen 29(1):58–62. 10.1002/(sici)1098-2280(1997)29:1<58::aid-em8>3.0.co;2-9.9020308
Herrero ME, Arand M, Hengstler JG, . 1997. Recombinant expression of human microsomal epoxide hydrolase protects V79 Chinese hamster cells from styrene oxide- but not from ethylene oxide-induced DNA strand breaks. Environ Mol Mutagen 30(4):429–439. 10.1002/(sici)1098-2280(1997)30:4<429::aid-em8>3.0.co;2-d.9435884
Hinz R, Mannetje A, Glass B, . 2020. Exposures to fumigants and residual chemicals in workers handling cargo from shipping containers and export logs in New Zealand. Ann Work Expo Health 64(8):826–837. 10.1093/annweh/wxaa052.32504467
Hochberg V, Shi XC, Moorman W, . 1990. Induction of micronuclei in rat bone marrow and spleen cells by varied dose-rate of ethylene oxide. Environ Mol Mutagen 15:26.
Hogstedt LC. 1988. Epidemiological studies on ethylene oxide and cancer: an updating. IARC Sci Publ 89(89):265–270.
Hogstedt C, Maimqvist N, Wadman B. 1979a. Leukemia in workers exposed to ethylene oxide. J Am Med Assoc 241(11):1132–1133.
Hogstedt C, Rohlen O, Berndtsson BS, . 1979b. A cohort study of mortality and cancer incidence in ethylene oxide production workers. Br J Ind Med 36:276–280.508639
Hogstedt C, Aringer L, Gustavsson A. 1986. Epidemiologic support for ethylene oxide as a cancer-causing agent. J Am Med Assoc 255(12):1575–1578.
Hogstedt B, Bergmark E, Tornqvist M, . 1990. Chromosomal aberrations and micronuclei in lymphocytes in relation to alkylation of hemoglobin in workers exposed to ethylene oxide and propylene oxide. Hereditas 113(2):133–138. 10.1111/j.1601-5223.1990.tb00076.x.2079438
Hollingsworth RL, Rowe VK, Oyen F, . 1956. Toxicity of ethylene oxide determined on experimental animals. AMA Arch Ind Health 13(3):217–227.13291899
Hughes TJ, Simmons DM, Monteith LG, . 1987. Vaporization technique to measure mutagenic activity of volatiles organic chemicals in the Ames/Salmonella assay. Environ Mutagen 9(4):421–441. 10.1002/em.2860090408.3556157
IARC. 1976. Ethylene oxide. IARC monographs on the evaluation of carcinogenic risk of chemicals to man: Cadmium, nickel, some epoxides, miscellaneous industrial chemicals and general considerations of volatile anaesthetics. Lyon, France: International Agency for Research on Cancer. Vol. 11, 157–167. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono11.pdf. March 20, 2019.
IARC. 1985. Ethylene oxide. IARC monographs on the evaluation of carcinogenic risk of chemicals to man: Allyl compounds, aldehydes, epoxides, peroxides. Lyon, France: International Agency for Research on Cancer. Vol. 36, 189–226. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono36.pdf. March 20, 2019.
IARC. 1987. Ethylene oxide (Group 2A). In: IARC monographs on the evaluation of carcinogenic risks to humans: Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Supplement 7. Lyon, France: International Agency for Research on Cancer, 205–207.
IARC. 1994. Ethylene oxide. IARC monographs on the evaluation of carcinogenic risks to humans: Some industrial chemicals. International Agency for Research on Cancer. Vol. 60, 73–159. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono60-7.pdf. March 20, 2019.
IARC. 2008. Ethylene oxide. IARC monographs on the evaluation of carcinogenic risks to humans: 1,3-Butadiene, ethylene oxide and vinyl halides (vinyl fluoride, vinyl chloride and vinyl bromide). Lyon, France: International Agency for Research on Cancer. Vol. 97, 185–309. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono97-7.pdf. March 20, 2019.
IARC. 2012. Ethylene oxide. IARC monographs on the evaluation of carcinogenic risks to humans: Chemical agents and related occupations. Lyon, France: International Agency for Research on Cancer. Vol. 100F, 379–400. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono100F-28.pdf. December 11, 2018.
IARC. 2021. Agents classified by the IARC Monographs, volumes 1-128. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. February 3, 2021.
IRIS. 2021. Alphabetical index. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/atoz.cfm. February 3, 2021.
Jacobson KH, Hackley WB, Feinsilver L. 1956. The toxicity of inhaled ethylene oxide and propylene oxide vapors: Acute and chronic toxicity of ethylene oxide and acute toxicity of propylene oxide. AMA Arch Ind Health 13(3):237–244.13291901
Jay WM, Swift TR, Hull DS. 1982. Possible relationship of ethylene oxide exposure to cataract formation. Am J Ophthalmol 93(6):727–732. 10.1016/0002-9394(82)90468-8.7091260
J-CHECK. 2019. #28: Biodegradation in water: Screening tests [CASRN 75-21-8]. Japan CHEmicals Collaborative Knowledge database. Tokyo, Japan: National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck//template.action?ano=479&mno=2-218&cno=75-21-8&r. February 18, 2019.
Jenssen D, Ramel C. 1980. The micronucleus test as part of a short-term mutagenicity test program for the prediction of carcinogenicity evaluated by 143 agents tested. Mutat Res 75(2):191–202. 10.1016/0165-1110(80)90014-7.7366601
Joshi SB, Dodge MC, Bufalini JJ. 1982. Reactivities of selected organic compounds and contamination effects. Atmos Environ 16:1301–1310.
Joyner RE. 1964. Chronic toxicity of ethylene oxide: A study of human responses to long-term low-level exposures. Arch Environ Health 8:700–710. 10.1080/00039896.1964.10663741.14120567
Kaido M, Mori K, Koide O. 1992. Testicular damage caused by inhalation of ethylene oxide in rats: light and electron microscopic studies. Toxicol Pathol 20(1):32–43. 10.1177/019262339202000105.1411129
Kamel MM, Hewehy MAI, Hussein AHM, . 2011. Biological monitoring of the ethylene oxide gas effects on medical utilities sterilization exposed staff. East J Med 16(1):44–52.
Karacalar A, Karacalar SA. 2000. Chemical burns due to blood pressure cuff sterilized with ethylene oxide. Burns 26(8):760–763. 10.1016/s0305-4179(00)00054-1.11024613
Karelova J, Jablonicka A, Vargova M. 1987. Results of cytogenetic testing of workers exposed to ethylene oxide. J Hyg Epidemiol Microbiol Immunol 31(2):119–126.
Kelsey KT, Wiencke JK, Eisen EA, . 1988. Persistently elevated sister chromatid exchanges in ethylene oxide-exposed primates: The role of a subpopulation of high frequency calls. Cancer Res 48:5045–5050.3409233
Kelsey KT, Wiencke JK, Eisen EA, . 1989. Sister chromatid exchange in chronic ethylene oxide-exposed primates: unexpected effects of in vitro culture duration, incubation temperature, and serum supplementation. Cancer Res 49(7):1727–1731.2493984
Kerre S, Goossens A. 2009. Allergic contact dermatitis to ethylene oxide. Contact Dermatitis 61(1):47–48. 10.1111/j.1600-0536.2009.01545.x.19659965
Khan FI, Husain T, Abbasi SA. 2002. Design and evaluation of safety measures using a newly proposed methodology “SCAP”. J Loss Prev Process Ind 15(2):129–146. 10.1016/S0950-4230(01)00026-2.
Kiesselbach N, Ulm K, Lange HJ, . 1990. A multicentre mortality study of workers exposed to ethylene oxide. Br J Ind Med 47(3):182–188. 10.1136/oem.47.3.182.2183875
Kilbey BJ, Kolmark HG. 1968. A mutagenic after-effect associated with ethylene oxide in Neurospora crassa. Mol Gen Genet 101(2):185–188. 10.1007/BF00336584.5683006
Kirman CR, Hays SM. 2017. Derivation of endogenous equivalent values to support risk assessment and risk management decisions for an endogenous carcinogen: Ethylene oxide. Regul Toxicol Pharmacol 91:165–172. 10.1016/j.yrtph.2017.10.032.29111443
Kirman CR, Li AA, Sheehan PJ, . 2021. Ethylene oxide review: characterization of total exposure via endogenous and exogenous pathways and their implications to risk assessment and risk management. J Toxicol Environ Health 24(1):1–29. 10.1080/10937404.2020.1852988.
Kligerman AD, Erexson GL, Phelps ME, . 1983. Sister-chromatid exchange induction in peripheral blood lymphocytes of rats exposed to ethylene oxide by inhalation. Mutat Res 120(1):37–44. 10.1016/0165-7992(83)90071-4.6835260
Koga M, Hori H, Tanaka I, . 1987. [Analysis of urinary metabolites of rats exposed to ethylene oxide]. J UOEH 9(2):167–170. 10.7888/juoeh.9.167. (Japanese)3616261
Kolman A. 1984. Protective effect of low doses in mutagenesis with ethylene oxide in E. coli. Mutat Res 139(4):167–171. 10.1016/0165-7992(84)90122-2.6371519
Kolman A. 1985. Effect of deficiency in excision repair and umuC function on the mutagenicity with ethylene oxide in the lacI gene of E. coli. Mutat Res 146(1):43–46. 10.1016/0167-8817(85)90053-7.3889607
Kolman A, Naslund M. 1987. Mutagenicity testing of ethylene oxide in Escherichia coli strains with different repair capacities. Environ Mol Mutagen 10(3):311–315. 10.1002/em.2850100310.3315654
Kolman A, Naslund M, Granath F. 1989a. Modifying action of gamma-radiation in mutagenesis of E. coli WU36-10 induced by ethylene oxide, ethyl methanesulfonate and methyl methanesulfonate. Mutat Res 212(2):269–274.2659982
Kolman A, Naslund M, Osterman-Golkar S, . 1989b. Comparative studies of in vitro transformation by ethylene oxide and gamma-radiation of C3H/10T1/2 cells. Mutagenesis 4(1):58–61.2654552
Kolman A, Naslund M, Osterman-Golkar S. 1990. Studies of the rad-equivalence of ethylene oxide in the presence and absence of 12-O-tetradecanoylphorbol-13-acetate (TPA) in C3H/10T1/2 cells. Toxicol Lett 53(3):307–313. 10.1016/0378-4274(90)90235-e.2237937
Kolman A, Bohusova T, Lambert B, . 1992. Induction of 6-thioguanine-resistant mutants in human diploid fibroblasts in vitro with ethylene oxide. Environ Mol Mutagen 19(2):93–97. 10.1002/em.2850190203.1541259
Kolmark G, Westergaard M. 1953. Further studies on chemically induced reversions at the adenine locus of Neurospora. Hereditas 39:209–224.
Kolmark HG, Kilbey BJ. 1968. Kinetic studies of mutation induction by epoxides in Neurospora crassa. Mol Gen Genet 101(2):89–98. 10.1007/BF00336573.5683008
Krell K, Jacobson ED, Selby K. 1979. Mutagenic effect on L5178Y mouse lymphoma cells by growth in ethylene oxide-sterilized polycarbonate flasks. In Vitro 15(5):326–328. 10.1007/BF02616138.478562
Krishnan K, Gargas ML, Fennell TR, . 1992. A physiologically based description of ethylene oxide dosimetry in the rat. Toxicol Ind Health 8(3):121–140. 10.1177/074823379200800301.1502695
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuzuhara S, Kanazawa I, Nakanishi T, . 1983. Ethylene oxide polyneuropathy. Neurology 33(3):377–380. 10.1212/wnl.33.3.377.6298660
LakeCounty. 2020. EtO monitoring results. Waukegan, IL: Lake County Health Department & Community Health Center. https://www.lakecountyil.gov/4188/EtO-Monitoring-Results. July 12, 2021.
Lambert B, Lindblad A. 1980. Sister chromatid exchange and chromosome aberrations in lymphocytes of laboratory personnel. J Toxicol Environ Health 6(5–6):1237–1243. 10.1080/15287398009529942.7463515
Lambert B, Andersson B, Bastlova T, . 1994. Mutations induced in the hypoxanthine phosphoribosyl transferase gene by three urban air pollutants: acetaldehyde, benzo[a]pyrene diolepoxide, and ethylene oxide. Environ Health Perspect 102 Suppl 4:135–138. 10.1289/ehp.94102s4135.
LaMontagne AD, Oakes JM, Lopez Turley RN. 2004. Long-term ethylene oxide exposure trends in US hospitals: relationship with OSHA regulatory and enforcement actions. Am J Public Health 94(9):1614–1619. 10.2105/ajph.94.9.1614.15333324
Laurent C. 1988. SCE increases after an accidental acute inhalation exposure to ethylene oxide and recovery to normal after 2 years. Mutat Res 204:711–717.3352653
Laurent C, Frederic J, Leonard AY. 1984. Sister chromatid exchange frequency in workers exposed to high levels of ethylene oxide, in a hospital sterilization service. Int Arch Occup Environ Health 54(1):33–43. 10.1007/BF00378726.6724701
Lerda D, Rizzi R. 1992. Cytogenetic study of persons occupationally exposed to ethylene oxide. Mutat Res 281(1):31–37. 10.1016/0165-7992(92)90033-e.1371589
Lerman Y, Ribak J, Skulsky M, . 1995. An outbreak of irritant contact dermatitis from ethylene oxide among pharmaceutical workers. Contact Dermatitis 33(4):280–281.8654093
Lewis SE, Barnett LB, Felton C, . 1986. Dominant visible and electrophoretically expressed mutations induced in male mice exposed to ethylene oxide by inhalation. Environ Mutagen 8(6):867–872. 10.1002/em.2860080609.3780618
Lewis SE, Barnett LB, Akeson EC, . 1990. A new dominant neurological mutant induced in the mouse by ethylene oxide. Mutat Res 229(2):135–139. 10.1016/0027-5107(90)90088-l.2320026
Li F, Segal A, Solomon JJ. 1992. In vitro reaction of ethylene oxide with DNA and characterization of DNA adducts. Chem Biol Interact 83(1):35–54. 10.1016/0009-2797(92)90090-8.1643667
Long FA, Pritchard JG. 1956. Hydrolysis of substituted ethylene oxides in H2O18 solutions. J Am Chem Soc 78:2663–2667.
Lorenti Garcia C, Darroudi F, Tates AD, . 2001. Induction and persistence of micronuclei, sister-chromatid exchanges and chromosomal aberrations in splenocytes and bone-marrow cells of rats exposed to ethylene oxide. Mutat Res 492(1–2):59–67. 10.1016/s1383-5718(01)00149-8.11377244
Lynch DW, Lewis TR, Moorman WJ, . 1984a. Effects on monkeys and rats of long-term inhalation exposure to ethylene oxide: Major findings of the NIOSH study. In: Inhospital ethylene oxide sterilization-current issues in ethylene oxide toxicity and occupational exposure. Arlington, VA: Association for the Advancement of Medical Instrumentation, 7–10.
Lynch DW, Lewis TR, Moorman WJ, . 1984b. Carcinogenic and toxicologic effects of inhaled ethylene oxide and propylene oxide in F344 rats. Toxicol Appl Pharmacol 76:69–84.6484993
Lynch DW, Lewis TR, Moorman WJ, . 1984c. Sister-chromatid exchanges and chromosome aberrations in lymphocytes from monkeys exposed to ethylene oxide and propylene oxide by inhalation. Toxicol Appl Pharmacol 76:85–95.6484994
Major J, Jakab MG, Tompa A. 2001. Genotoxicological investigation of hospital nurses occupationally exposed to ethylene oxide. II. HPRT mutation frequencies Cent Eur J Occup Environ Med 7(3/4):195–208.
Marsh GM, Keeton KA, Riordan AS, . 2019. Ethylene oxide and risk of lympho-hematopoietic cancer and breast cancer: a systematic literature review and meta-analysis. Int Arch Occup Environ Health 92(7):919–939. 10.1007/s00420-019-01438-z.31111206
Mashima S, Ikeda Y. 1958. Selection of mutagenic agents by the Streptomyces reverse mutation test. Appl Microbiol 6(1):45–49. 10.1128/am.6.1.45-49.1958.13509655
Matsuoka M. 1988. [Effects of chronic exposure of ethylene oxide, especially on heme metabolism]. J UEOH 10(1):77–88. (Japanese)
Matsuoka M, Igisu H, Inoue N, . 1990. Inhibition of creatine kinase activity by ethylene oxide. Br J Ind Med 47(1):44–47. 10.1136/oem.47.1.44.2310706
Mayer J, Warburton D, Jeffrey AM, . 1991. Biologic markers in ethylene oxide-exposed workers and controls. Mutat Res 248(1):163–176. 10.1016/0027-5107(91)90098-9.2030705
McCarver DG, Hines RN. 2002. The ontogeny of human drug-metabolizing enzymes: phase II conjugation enzymes and regulatory mechanisms. J Pharmacol Exp Ther 300(2):361–366. 10.1124/jpet.300.2.361.11805192
McDonald TO, Kasten K, Hervey R, . 1977. Acute ocular toxicity for normal and irritated rabbit eyes and subacute ocular toxicity for ethylene oxide, ethylene chlorohydrin, and ethylene glycol. Bull Parenter Drug Assoc 31(1):25–32.831896
McLaughlin RS. 1946. Chemical burns of the human cornea. Am J Ophthalmol 29(11):1355–1362. 10.1016/0002-9394(46)92031-4.20276970
Mertes I, Fleischmann R, Glatt HR, . 1985. Interindividual variations in the activities of cytosolic and microsomal epoxide hydrolase in human liver. Carcinogenesis 6(2):219–223. 10.1093/carcin/6.2.219.3971488
Migliore L, Rossi AM, Loprieno N. 1982. Mutagenic action of structurally related alkene oxides on Schizosaccharomyces pombe: The influence, ‘in vitro’, of mouse-liver metabolizing system. Mutat Res 102:425–437.7177150
Mikoczy Z, Tinnerberg H, Bjork J, . 2011. Cancer incidence and mortality in Swedish sterilant workers exposed to ethylene oxide: updated cohort study findings 1972-2006. Int J Environ Res Public Health 8(6):2009–2019. 10.3390/ijerph8062009.21776215
Morgan RW, Claxton KW, Divine BJ, . 1981. Mortality among ethylene oxide workers. J Occup Med 23(11):767–770. 10.1097/00043764-198111000-00011.7320776
Mori K, Kaido M, Fujishiro K, . 1991a. Dose dependent effects of inhaled ethylene oxide on spermatogenesis in rats. Br J Ind Med 48(4):270–274.2025594
Mori K, Kaido M, Fujishiro K, . 1991b. Preventive effects of methylcobalamin on the testicular damage induced by ethylene oxide. Arch Toxicol 65(5):396–401.1929855
Morpurgo G. 1963. Induction of mitotic crossing-over in Aspergillus nidulans by bifunctional alkylating agents. Genetics 48(9):1259–1263.17248183
Muller M, Kramer A, Angerer J, . 1998. Ethylene oxide-protein adduct formation in humans: influence of glutathione-S-transferase polymorphisms. Int Arch Occup Environ Health 71(7):499–502. 10.1007/s004200050312.9826084
Nagata H, Ohkoshi N, Kanazawa I, . 1992. Rapid axonal transport velocity is reduced in experimental ethylene oxide neuropathy. Mol Chem Neuropathol 17(3):209–217. 10.1007/BF03160011.1283512
Nakashima K, Furutani A, Higashi K, . 1987. Glutathione contents in rat livers after acute and chronic exposure to ethylene oxide. J UOEH 9(4):355–359. 10.7888/juoeh.9.355.3438609
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, 15–35.
Neeper-Bradley TL, Kubena MF. 1993. Ethylene oxide: Developmental toxicity study of maternally inhaled vapor in CD rats. Praxair. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0537695. EPA Document No. 86-930000252.
NIOSH. 1981. Ethylene oxide (EtO): Evidence of carcinogenicity. NIOSH current intelligence bulletin 35. Cincinnati, OH: National Institute for Occupational Safety and Health. PB85119121. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB85119121.xhtml. March 21, 2019.
NIOSH. 1982. Teratogenic study of ethylene and propylene oxide and n-butyl acetate. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83258038.
NIOSH. 1987. A pharmacokinetic/mechanism-based analysis of the carcinogenic risk of ethylene oxide. National Institute for Occupational Safety and Health. PB88188784. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88188784.xhtml. March 21, 2019.
NIOSH. 1994. Ethylene oxide. Immediately Dangerous to Life or Health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/75218.html. December 11, 2018.
NIOSH. 2007. Ethylene oxide. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2005-149/pdfs/2005-149.pdf. March 20,2019.
NIOSH. 2016. Ethylene oxide. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0275.html. December 11, 2018.
NIOSH. 2019. Ethylene oxide. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0275.html. February 17, 2021.
Nivard MJ, Czene K, Segerback D, . 2003. Mutagenic activity of ethylene oxide and propylene oxide under XPG proficient and deficient conditions in relation to N-7-(2-hydroxyalkyl)guanine levels in Drosophila. Mutat Res 529(1–2):95–107. 10.1016/s0027-5107(03)00111-8.12943923
NLM. 2021. PubChem data: Ethylene oxide (CASRN 75-21-8). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Ethylene-oxide. July 12, 2021.
Norman SA, Berlin JA, Soper KA, . 1995. Cancer incidence in a group of workers potentially exposed to ethylene oxide. Int J Epidemiol 24(2):276–284. 10.1093/ije/24.2.276.7635586
NTP. 1987 Toxicology and carcinogenesis studies of ethylene oxide in B6C3F1 mice (inhalation studies). National Toxicology Program. NTP TR 326. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr326.pdf. June 25, 2019.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/hat/review/index-2.html. March 21, 2019.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Ethylene oxide. Report on carcinogens, 14^th^ edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/ethyleneoxide.pdf. December 11, 2018.
Nygren J, Cedervall B, Eriksson S, . 1994. Induction of DNA strand breaks by ethylene oxide in human diploid fibroblasts. Environ Mol Mutagen 24(3):161–167. 10.1002/em.2850240304.7957119
OEHHA. 2008. Appendix D.3 Chronic RELs and toxicity summaries using the previous version of the Hot Spots Risk Assessment guidelines (OEHHA 1999). Technical supporting document for noncancer RELs Sacramento, CA: Office of Environmental Health Hazard Assessment, California Environmental Protection Agency. https://oehha.ca.gov/media/downloads/crnr/appendixd3final.pdf. March 19, 2019.
Ohnishi A, Inoue N, Yamamoto T, . 1985. Ethylene oxide induces central-peripheral distal axonal degeneration of the lumbar primary neurones in rats. Br J Ind Med 42(6):373–379. 10.1136/oem.42.6.373.2988600
Ohnishi A, Inoue N, Yamamoto T, . 1986. Ethylene oxide neuropathy in rats. Exposure to 250 ppm. J Neurol Sci 74(2–3):215–221. 10.1016/0022-510x(86)90106-1.3016198
Olsen GW, Lacy SE, Bodner KM, . 1997. Mortality from pancreatic and lymphopoietic cancer among workers in ethylene and propylene chlorohydrin production. Occup Environ Med 54(8):592–598. 10.1136/oem.54.8.592.9326163
Ong T, Bi HK, Xing S, . 1993. Induction of sister chromatid exchange in spleen and bone marrow cells of rats exposed by inhalation to different dose rates of ethylene oxide. Environ Mol Mutagen 22(3):147–151. 10.1002/em.2850220306.8404874
OSHA. 1988. Occupational exposure to ethylene oxide. Occupational Safety and Health Administration. Fed Regist 53(13):1724–1737.
OSHA. 2018a. 1910.1047 Ethylene oxide. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1047. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol6/pdf/CFR-2018-title29-vol6-sec1910-1047.pdf. December 11, 2018.
OSHA. 2018b. 1915.1047 Ethylene oxide. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1047. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol7/pdf/CFR-2018-title29-vol7-sec1915-1047.pdf. December 11, 2018.
OSHA. 2018c. 1926.1147 Ethylene oxide. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1147. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol8/pdf/CFR-2018-title29-vol8-sec1926-1147.pdf. December 11, 2018.
OSHA. 2021a. Safety and health regulations for construction. Subpart Z - Toxic and Hazardous Substances. Ethylene oxide. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1147. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.1147. February 17, 2021.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Ethylene oxide. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1047. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1047. February 17, 2021.
OSHA. 2021c. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Ethylene oxide. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1047. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1047. February 17, 2021.
Osterman-Golkar SM, Bond JA, Ward JB, . 1993. Use of haemoglobin adducts for biomonitoring exposure to 1,3-butadiene. IARC Sci Publ 127(127):127–134.
Parod RJ. 2014. Ethylene oxide. In: Encyclopedia of toxicology. 3^rd^ ed. London, England: Elsevier Inc., 535–538. 10.1016/B978-0-12-386454-3.00021-X.
Pero RW, Widegren B, Högstedt B, . 1981. In vivo and in vitro ethylene oxide exposure of human lymphocytes assessed by chemical stimulation of unscheduled DNA synthesis. Mutat Res 83(2):271–289. 10.1016/0027-5107(81)90011-7.7300850
Pfeiffer EH, Dunkelberg H. 1980. Mutagenicity of ethylene oxide and propylene oxide and of the glycols and halohydrins formed from them during the fumigation of foodstuffs. Food Cosmet Toxicol 18:115–118.6993314
Picut CA, Aoyama H, Holder JW, . 2003. Bromoethane, chloroethane and ethylene oxide induced uterine neoplasms in B6C3F1 mice from 2-year NTP inhalation bioassays: pathology and incidence data revisited. Exp Toxicol Pathol 55(1):1–9. 10.1078/0940-2993-00303.12940622
Poirier V, Papadopoulo D. 1982. Chromosomal aberrations induced by ethylene oxide in a human amniotic cell line in vitro. Mutat Res 104(4–5):255–260. 10.1016/0165-7992(82)90153-1.7110163
Popp W, Vahrenholz C, Przygoda H, . 1994. DNA-protein cross-links and sister chromatid exchange frequencies in lymphocytes and hydroxyethyl mercapturic acid in urine of ethylene oxide-exposed hospital workers. Int Arch Occup Environ Health 66(5):325–332. 10.1007/BF00378365.7896417
Potter D, Blair D, Davies R, . 1989. The relationships between alkylation of haemoglobin and DNA in Fischer 344 rats exposed to [14C]ethylene oxide. Arch Toxicol Suppl 13:254–257. 10.1007/978-3-642-74117-3_44.2774941
Preston RJ. 1999. Cytogenetic effects of ethylene oxide, with an emphasis on population monitoring. Crit Rev Toxicol 29(3):263–282. 10.1080/10408449991349212.10379809
Rajendran S, Muthu M. 1981. Detection of acrylonitrile and ethylene oxide in air and fumigated foodstuffs. Bull Environ Contam Toxicol 27(3):426–431. 10.1007/BF01611043.7296077
Ramboll. 2019. Ambient air monitoring report ethylene oxide background concentrations in Chicago metro area. Ramboll US Corporation. Sterigenics US, LLC. https://static1.squarespace.com/static/5b8457322714e5cbd33c889a/t/5c4c5cad1ae6cfaa21e6cd7e/1548508356697/EO+background+study+report+1-24-19.pdf. February 27, 2020.
Rannug U, Göthe R, Wachtmeister CA. 1976. The mutagenicity of chloro-ethylene oxide, chloroacetaldehyde, 2-chloroethanol and chloroacetic acid, conceivable metabolites of vinyl chloride. Chem Biol Interact 12:251–263.767010
Recio L, Donner M, Abernethy D, . 2004. In vivo mutagenicity and mutation spectrum in the bone marrow and testes of B6C3F1 lacI transgenic mice following inhalation exposure to ethylene oxide. Mutagenesis 19(3):215–222. 10.1093/mutage/geh017.15123787
RePORTER. 2021. Ethylene oxide. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. March 19, 2019.
Ribeiro LR, Rabello-Gay MN, Salvadori DMF, . 1987. Cytogenic effects of inhaled ethylene oxide in somatic and germ cells of mice. Arch Toxicol 59:332–335.3579597
Ribeiro LR, Salvadori DM, Rios AC, . 1994. Biological monitoring of workers occupationally exposed to ethylene oxide. Mutat Res 313(1):81–87. 10.1016/0165-1161(94)90035-3.8047079
Richmond GW, Abrahams RH, Nemenzo JH, . 1985. An evaluation of possible effects on health following exposure to ethylene oxide. Arch Environ Health 40(1):20–25. 10.1080/00039896.1985.10545884.3994416
Romaguera C, Vilaplana J. 1998. Airborne occupational contact dermatitis from ethylene oxide. Contact Dermatitis 39(2):85. 10.1111/j.1600-0536.1998.tb05841.x.9746191
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rowland AS, Baird DD, Shore DL, . 1996. Ethylene oxide exposure may increase the risk of spontaneous abortion, preterm birth, and postterm birth. Epidemiology 7(4):363–368. 10.1097/00001648-199607000-00005.8793361
Russell LB, Cumming RB, Hunsicker PR. 1984. Specific-locus mutation rates in the mouse following inhalation of ethylene oxide, and application of the results to estimation of human genetic risk. Mutat Res 129(3):381–388. 10.1016/0027-5107(84)90093-9.6513965
Rusyn I, Asakura S, Li Y, . 2005. Effects of ethylene oxide and ethylene inhalation on DNA adducts, apurinic/apyrimidinic sites and expression of base excision DNA repair genes in rat brain, spleen, and liver. DNA Repair (Amst) 4(10):1099–1110. 10.1016/j.dnarep.2005.05.009.16051529
Rutledge JC, Generoso WM. 1989. Fetal pathology produced by ethylene oxide treatment of the murine zygote. Teratology 39(6):563–572. 10.1002/tera.1420390607.2788934
Saillenfait AM, Gallissot F, Bonnet P, . 1996. Developmental toxicity of inhaled ethylene oxide in rats following short-duration exposure. Fundam Appl Toxicol 34(2):223–227. 10.1006/faat.1996.0191.8954751
Salinas E, Sasich L, Hall DH, . 1981. Acute ethylene oxide intoxication. Drug Intell Clin Pharm 15(5):384–386. 10.1177/106002808101500509.7274051
Sarto F, Cominato I, Pinton AM, . 1984. Workers exposed to ethylene oxide have increased incidence of sister chromatid exchange. IARC Sci Publ 59(59):413–419.
Sarto F, Cionfero E, Bartolucci GB, . 1987. Sister chromatid exchanges and DNA repair capability in sanitary workers exposed to ethylene oxide: Evaluation of the dose-effect relationship. Am J Ind Med 12(5):625–637. 10.1002/ajim.4700120515.3687955
Sarto F, Tomanin R, Giacomelli L, . 1990. The micronucleus assay in human exfoliated cells of the nose and mouth: application to occupational exposures to chromic acid and ethylene oxide. Mutat Res 244(4):345–351. 10.1016/0165-7992(90)90083-v.2385249
Sarto F, Tornqvist MA, Tomanin R, . 1991. Studies of biological and chemical monitoring of low-level exposure to ethylene oxide. Scand J Work Environ Health 17(1):60–64. 10.5271/sjweh.1733.2047808
Scheick C, Spiteller G, Dasenbrock C. 1997. Thiodiacetic acid--a metabolite of Ethylene oxide. Z Naturforsch C J Biosci 52(1–2):70–76.9090069
Schröder JM, Hoheneck M, Weis J, . 1985. Ethylene oxide polyneuropathy: clinical follow-up study with morphometric and electron microscopic findings in a sural nerve biopsy. J Neurol 232(2):83–90. 10.1007/BF00313906.2991474
Schulte PA, Boeniger M, Walker JT, . 1992. Biologic markers in hospital workers exposed to low levels of ethylene oxide. Mutat Res 278(4):237–251. 10.1016/s0165-1218(10)80003-5.1373860
Scudamore KA, Heuser SG. 1971. Ethylene oxide and its persistent reaction products in wheat flour and other commodities: Residues from fumigation or sterilisation, and effects of processing. Pestic Sci 2(2):80–91. 10.1002/ps.2780020207.
Sega GA, Generoso EE. 1988. Measurement of DNA breakage in spermiogenic germ-cell stages of mice exposed to ethylene oxide, using an alkaline elution procedure. Mutat Res 197:93–99.3336375
Sega GA, Generoso EE, Brimer PA. 1988. Inhalation exposure-rate of ethylene oxide affects the level of DNA breakage and unscheduled DNA synthesis in spermiogenic stages of the mouse. Mutat Res 209(3–4):177–180. 10.1016/0165-7992(88)90038-3.3193982
Sega GA, Brimer PA, Generoso EE. 1991. Ethylene oxide inhalation at different exposure-rates affects binding levels in mouse germ cells and hemoglobin. Possible explanation for the effect. Mutat Res 249(2):339–349. 10.1016/0027-5107(91)90009-d.2072977
Segerback D. 1983. Alkylation of DNA and hemoglobin in the mouse following exposure to ethene and ethene oxide. Chem Biol Interact 45(2):139–151. 10.1016/0009-2797(83)90064-9.6883570
Segerback D. 1990. Reaction products in hemoglobin and DNA after in vitro treatment with ethylene oxide and N-(2-hydroxyethyl)-N-nitrosourea. Carcinogenesis 11(2):307–312. 10.1093/carcin/11.2.307.2302758
Sexton RJ, Henson EV. 1949. Dermatological injuries by ethylene oxide. J Ind Hyg Toxicol 31(5):297–300.18148651
Sexton RJ, Henson EV. 1950. Experimental ethylene oxide human skin injuries. AMA Arch Ind Hyg Occup Med 2(5):549–564.14777190
Shore RE, Gardner MJ, Pannett B. 1993. Ethylene oxide: an assessment of the epidemiological evidence on carcinogenicity. Br J Ind Med 50(11):971–997. 10.1136/oem.50.11.971.8280635
Shupack JL, Andersen SR, Romano SJ. 1981. Human skin reactions to ethylene oxide. J Lab Clin Med 98:723–729.7299242
Simmon VF. 1981. Applications of the Salmonella/microsome assay. In: Stich HP, San RHC, eds. Short-term tests for chemical carcinogens. New York, NY: Springer, 120–126. 10.1007/978-1-4612-5847-6_12.
Sisk SC, Pluta LJ, Meyer KG, . 1997. Assessment of the in vivo mutagenicity of ethylene oxide in the tissues of B6C3F1 lacI transgenic mice following inhalation exposure. Mutat Res 391(3):153–164. 10.1016/s1383-5718(97)00063-6.9268040
Smyth HF, Seaton J, Fischer L. 1941. The single dose toxicity of some glycols and derivatives. J Ind Hyg Toxicol 23:259–268.
Snellings WM, Maronpot RR, Zelenak JP, . 1982a. Teratology study in Fischer 344 rats exposed to ethylene oxide by inhalation. Toxicol Appl Pharmacol 64:476–481.7135397
Snellings WM, Zelenak JP, Weil CS. 1982b. Effects on reproduction in Fischer 344 rats exposed to ethylene oxide by inhalation for one generation. Toxicol Appl Pharmacol 63:382–388.7101299
Snellings WM, Weil CS, Maronpot RR. 1984a. A subchronic inhalation study on the toxicologic potential of ethylene oxide in B6C3F1 mice. Toxicol Appl Pharmacol 76:510–518.6506076
Snellings WM, Weil CS, Maronpot RR. 1984b. A two-year inhalation study of the carcinogenic potential of ethylene oxide in Fischer 344 rats. Toxicol Appl Pharmacol 75(1):105–117.6464016
Snellings WM, Nachreiner DJ, Pottenger LH. 2011. Ethylene oxide: acute four-hour and one-hour inhalation toxicity testing in rats. J Toxicol 2011:910180. 10.1155/2011/910180.21785591
Staples CA, Gulledge W. 2006. An environmental fate, exposure and risk assessment of ethylene oxide from diffuse emissions. Chemosphere 65(4):691–698. 10.1016/j.chemosphere.2006.01.047.16516948
Stayner L, Steenland K, Greife A, . 1993. Exposure-response analysis of cancer mortality in a cohort of workers exposed to ethylene oxide. Am J Epidemiol 138(10):787–798. 10.1093/oxfordjournals.aje.a116782.8237967
Steenland K, Stayner L, Greife A, . 1991. Mortality among workers exposed to ethylene oxide. N Engl J Med 324(20):1402–1407. 10.1056/NEJM199105163242004.2020295
Steenland K, Whelan E, Deddens J, . 2003. Ethylene oxide and breast cancer incidence in a cohort study of 7576 women (United States). Cancer Causes Control 14(6):531–539. 10.1023/a:1024891529592.12948284
Steenland K, Stayner L, Deddens J. 2004. Mortality analyses in a cohort of 18 235 ethylene oxide exposed workers: follow up extended from 1987 to 1998. Occup Environ Med 61(1):2–7.14691266
Stolley PD, Soper KA, Galloway SM, . 1984. Sister-chromatid exchanges in association with occupational exposure to ethylene oxide. Mutat Res 129(1):89–102. 10.1016/0027-5107(84)90127-1.6493252
Swaen GM, Slangen JM, Ott MG, . 1996. Investigation of a cluster of ten cases of Hodgkin’s disease in an occupational setting. Int Arch Occup Environ Health 68(4):224–228. 10.1007/BF00381432.8738351
Swaen GM, Burns C, Teta JM, . 2009. Mortality study update of ethylene oxide workers in chemical manufacturing: a 15 year update. J Occup Environ Med 51(6):714–723. 10.1097/JOM.0b013e3181a2ca20.19430313
Tan EL, Cumming RB, Hsie AW. 1981. Mutagenicity and cytotoxicity of ethylene oxide in the CHO/HGPRT system. Environ Mutagen 3:683–686.
Tanooka H. 1979. Application of Bacillus subtilis spores in the detection of gas mutagens: A case of ethylene oxide. Mutat Res 64:433–435.118382
Tardif R, Goyal R, Brodeur J, . 1987. Species differences in the urinary disposition of some metabolites of ethylene oxide. Fundam Appl Toxicol 9:448–453.3692004
Tates AD, Grummt T, Tornqvist M, . 1991. Biological and chemical monitoring of occupational exposure to ethylene oxide. Mutat Res 250(1–2):483–497. 10.1016/0027-5107(91)90205-3.1719390
Tates AD, Boogaard PJ, Darroudi F, . 1995. Biological effect monitoring in industrial workers following incidental exposure to high concentrations of ethylene oxide. Mutat Res 329(1):63–77. 10.1016/0027-5107(95)00018-e.7770077
Tates AD, van Dam FJ, Natarajan AT, . 1999. Measurement of HPRT mutations in splenic lymphocytes and haemoglobin adducts in erythrocytes of Lewis rats exposed to ethylene oxide. Mutat Res 431(2):397–415. 10.1016/s0027-5107(99)00182-7.10636004
Tavares R, Ramos P, Palminha J, . 1994. Transplacental exposure to genotoxins. Evaluation in haemoglobin of hydroxyethylvaline adduct levels in smoking and non-smoking mothers and their newborns. Carcinogenesis 15(6):1271–1274. 10.1093/carcin/15.6.1271.8020166
Taylor JS. 1977. Dermatologic hazards from ethylene oxide. Cutis 19(2):189–192.138576
TCEQ. 2020. Ethylene oxide carcinogenic dose-response assessment. Texas Commission On Environmental Quality. https://www.tceq.texas.gov/assets/public/implementation/tox/dsd/final/eto.pdf. July 14, 2021.
Teta MJ, Benson LO, Vitale JN. 1993. Mortality study of ethylene oxide workers in chemical manufacturing: a 10 year update. Br J Ind Med 50(8):704–709. 10.1136/oem.50.8.704.8398856
Teta MJ, Sielken RL, Valdez-Flores C. 1999. Ethylene oxide cancer risk assessment based on epidemiological data: application of revised regulatory guidelines. Risk Anal 19(6):1135–1155. 10.1023/a:1007086728854.10765453
Thier R, Bolt HM. 2000. Carcinogenicity and genotoxicity of ethylene oxide: new aspects and recent advances. Crit Rev Toxicol 30(5):595–608. 10.1080/10408440008951121.11055837
Thier R, Lewalter J, Kempkes M, . 1999. Haemoglobin adducts of acrylonitrile and ethylene oxide in acrylonitrile workers, dependent on polymorphisms of the glutathione transferases GSTT1 and GSTM1. Arch Toxicol 73(4–5):197–202. 10.1007/s002040050606.10463383
Thier R, Balkenhol H, Lewalter J, . 2001. Influence of polymorphisms of the human glutathione transferases and cytochrome P450 2E1 enzyme on the metabolism and toxicity of ethylene oxide and acrylonitrile. Mutat Res 482(1–2):41–46. 10.1016/s0027-5107(01)00208-1.11535247
Thiess AM. 1963. [Observations on the health hazards of ethylene oxide]. Arch Toxikol 20:127–140. (German)14114474
Thiess AM, Schwegler H, Fleig I, . 1981. Mutagenicity study of workers exposed to alkylene oxides (ethylene oxide/propylene oxide) and derivatives. J Occup Med 23(5):343–347.7241247
Tomkins DJ, Haines T, Lawrence M, . 1993. A study of sister chromatid exchange and somatic cell mutation in hospital workers exposed to ethylene oxide. Environ Health Perspect 101 Suppl 3(Suppl 3):159–164. 10.1289/ehp.93101s3159.
Tompa A, Major J, Jakab MG. 1999. Is breast cancer cluster influenced by environmental and occupational factors among hospital nurses in Hungary? Pathol Oncol Res 5(2):117–121. 10.1053/paor.1999.0182.10393363
TRI19. 2021. Ethylene oxide. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. October 11, 2018.
Tucker JD, Xu J, Stewart J, . 1986. Detection of sister chromatid exchanges induced by volatile genotoxicants. Teratog Carcinog Mutagen 6(1):15–21. 10.1002/tcm.1770060103.2426822
Tyler TR, McKelvey JA. 1982. Dose dependent disposition of 14C labeled ethylene oxide in rats. Union Carbide Corp. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0206060. EPA Document No. 878212056, 251–271.
Union Carbide. 1980. Long-term ethylene oxide inhalation study on rats: Report on cytogenetic studies of bone marrow cells: 12-month sacrifice interval. Union Carbide Corp. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0206060. EPA Document No. 878212057, 273–315.
van Duuren B, Orris L, Nelson N. 1965. Carcinogenicity of epoxides, lactones, and peroxy compounds. Part II. J Natl Cancer Inst 35:707–717.5841060
Van Sittert NJ, de Jong G, Clare MG, . 1985. Cytogenetic, immunological, and haematological effects in workers in an ethylene oxide manufacturing plant. Br J Ind Med 42(1):19–26. 10.1136/oem.42.1.19.3965011
van Sittert NJ, Boogaard PJ, Natarajan AT, . 2000. Formation of DNA adducts and induction of mutagenic effects in rats following 4 weeks inhalation exposure to ethylene oxide as a basis for cancer risk assessment. Mutat Res 447(1):27–48. 10.1016/s0027-5107(99)00208-0.10686305
Verschueren K. 1983. Ethylene oxide. In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 652–655.
Victorin K, Stahlberg M. 1988. A method for studying the mutagenicity of some gaseous compounds in Salmonella typhimurium. Environ Mol Mutagen 11:65–77.3276508
Vogel EW, Nivard MJ. 1997. The response of germ cells to ethylene oxide, propylene oxide, propylene imine and methyl methanesulfonate is a matter of cell stage-related DNA repair. Environ Mol Mutagen 29(2):124–135. 10.1002/(sici)1098-2280(1997)29:2<124::aid-em3>3.0.co;2-e.9118964
Vogel EW, Nivard MJ. 1998. Genotoxic effects of inhaled ethylene oxide, propylene oxide and butylene oxide on germ cells: sensitivity of genetic endpoints in relation to dose and repair status. Mutat Res 405(2):259–271. 10.1016/s0027-5107(98)00143-2.9748619
Von Oettingen W. 1939. Ethylene oxide. In: Supplement to occupation and health: Encyclopedia of hygiene, pathology, and social welfare. Geneva, Switzerland: International Labor Office, 2–4.
von Stedingk H, Vikstrom AC, Rydberg P, . 2011. Analysis of hemoglobin adducts from acrylamide, glycidamide, and ethylene oxide in paired mother/cord blood samples from Denmark. Chem Res Toxicol 24(11):1957–1965. 10.1021/tx200284u.21882862
Walker VE, Skopek TR. 1993. A mouse model for the study of in vivo mutational spectra: sequence specificity of ethylene oxide at the hprt locus. Mutat Res 288(1):151–162. 10.1016/0027-5107(93)90216-3.7686258
Walker VE, Fennell TR, Boucheron JA, . 1990. Macromolecular adducts of ethylene oxide: a literature review and a time-course study on the formation of 7-(2-hydroxyethyl)guanine following exposures of rats by inhalation. Mutat Res 233(1–2):151–164. 10.1016/0027-5107(90)90159-2.2233797
Walker VE, MacNeela JP, Swenberg JA, . 1992a. Molecular dosimetry of ethylene oxide: formation and persistence of N-(2-hydroxyethyl)valine in hemoglobin following repeated exposures of rats and mice. Cancer Res 52(16):4320–4327.1643629
Walker VE, Fennell TR, Upton PB, . 1992b. Molecular dosimetry of ethylene oxide: Formation and persistence of 7-(2-hydroxyethyl)guanine in DNA following repeated exposures of rats and mice. Cancer Res 52(16):4328–4334.1643630
Walker VE, Sisk SC, Upton PB, . 1997. In vivo mutagenicity of ethylene oxide at the hprt locus in T-lymphocytes of B6C3F1 lacI transgenic mice following inhalation exposure. Mutat Res 392(3):211–222. 10.1016/s1383-5718(97)00062-4.9294020
Watson WAF. 1966. Further evidence of an essential difference between the genetical effects of mono- and bifunctional alkylating agents. Mutat Res 3:455–457.5972698
Weast RC. 1985. Physical constants of organic compounds. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 66^th^ ed. Boca Raton, FL: CRC Press, C-273.
WHO. 1985. Environmental health criteria 55: Ethylene oxide. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc55.htm. March 21, 2019.
WHO. 2003. Ethylene oxide. Concise International Chemical Assessment Document. Geneva, Switzerland: World Health Organization. CICAD 54. https://www.who.int/ipcs/publications/cicad/en/cicad54.pdf?ua=1. July 14, 2021.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wong O, Trent LS. 1993. An epidemiological study of workers potentially exposed to ethylene oxide. Br J Ind Med 50(4):308–316. 10.1136/oem.50.4.308.8494770
Yager JW. 1987. Effect of concentration-time parameters on sister-chromatid exchanges induced in rabbit lymphocytes by ethylene oxide inhalation. Mutat Res 182(6):343–352. 10.1016/0165-1161(87)90076-8.3683433
Yager JW, Benz RD. 1982. Sister chromatid exchanges induced in rabbit lymphocytes by ethylene oxide after inhalation exposure. Environ Mutagen 4(2):121–134. 10.1002/em.2860040204.7075577
Yager JW, Hines CJ, Spear RC. 1983. Exposure to ethylene oxide at work increases sister chromatid exchanges in human peripheral lymphocytes. Science 219(4589):1221–1223.6828851
Yong LC, Schulte PA, Wiencke JK, . 2001. Hemoglobin adducts and sister chromatid exchanges in hospital workers exposed to ethylene oxide: effects of glutathione S-transferase T1 and M1 genotypes. Cancer Epidemiol Biomarkers Prev 10(5):539–550.11352866
Yong LC, Schulte PA, Kao CY, . 2007. DNA adducts in granulocytes of hospital workers exposed to ethylene oxide. Am J Ind Med 50(4):293–302. 10.1002/ajim.20443.17354254
Yoshida K, Bryant HE, Visser ND, . 1989. Determination of worker exposure to instantaneously emitted ethylene oxide in sterilization facilities. Appl Ind Hyg 4(7):166–170. 10.1080/08828032.1989.10390416.
Zampollo A, Zacchetti O, Pisati G. 1984. On ethylene oxide neurotoxicity: report of two cases of peripheral neuropathy. Ital J Neurol Sci 5(1):59–62. 10.1007/BF02043971.6330000
Zey JN, Mortimer VD, Elliott LJ. 1994. Ethylene oxide exposures to hospital sterilization workers from poor ventilation design. Appl Occup Environ Hyg 9(9):633–641. 10.1080/1047322X.1994.10388386.
Zhang LH, Jenssen D. 1994. Studies on intrachromosomal recombination in SP5/V79 Chinese hamster cells upon exposure to different agents related to carcinogenesis. Carcinogenesis 15(10):2303–2310. 10.1093/carcin/15.10.2303.7955071
Zhong BZ, Gu ZW, Whong WZ, . 1991. Comparative study of micronucleus assay and chromosomal aberration analysis in V79 cells exposed to ethylene oxide. Teratog Carcinog Mutagen 11(5):227–233. 10.1002/tcm.1770110502.1687900
Zhong G, James MO, Smeltz MG, . 2018. Age-related changes in expression and activity of human hepatic mitochondrial glutathione transferase zeta. Drug Metab Dispos 46(8):1118–1128. 10.1124/dmd.118.081810.29853471
Zijlstra JA, Vogel EW. 1988. The ratio of induced recessive lethals to ring-X loss has prognostic value in terms of functionality of chemical mutagens in Drosophila melanogaster. Mutat Res 201:27–38.2458528