# VERSION HISTORY

Date | Description
August 2022 | Final toxicological profile released
September 2020 | Draft for public comment toxicological profile released
December 1990 | Final toxicological profile released