# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Jennifer Przybyla, Ph.D. (Lead)
- Nickolette Roney, M.P.H.
- Henry Abadin, M.S.P.H.
- Breanna Alman, M.P.H.
- Brittany Szafran, D.V.M., Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- David W. Wohlers, Ph.D.
- Lynn Barber, M.S.
- Mario Citra, Ph.D.
- Gary L. Diamond, Ph.D.
- Lisa Ingerman, Ph.D., D.A.B.T.
- Julie M. Klotzbach, Ph.D.
- Kim Zaccaria, Ph.D., D.A.B.T.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA.

## PEER REVIEWERS

Peer Reviewers for the full profile:

1. Thomas E. McKone, Ph.D.; Professor Emeritus; School of Public Health; University of California; Berkeley, California
2. Kyle Steenland, Ph.D.; Professor, Department of Environmental Health; Professor, Department of Epidemiology; Rollins School of Public Health; Emory University; Atlanta, Georgia
3. Lewis Weinstock, Project Manager; Office of Air and Radiation; Office of Air Quality Planning & Standards; U.S. Environmental Protection Agency; Research Triangle Park, North Carolina
4. Timothy R. Fennell, Ph.D.; Senior Director, Analytical Chemistry and Pharmaceutics; RTI International; Durham, North Carolina
5. Ivan Rusyn, M.D., Ph.D.; Professor, Department of Veterinary Integrative Biosciences; College of Veterinary Medicine & Biomedical Sciences; Texas A&M University; College Station, Texas
6. James Wagner, Ph.D.; Associate Professor, Pathobiology and Diagnostic Investigation; College of Veterinary Medicine; Michigan State University; East Lansing, Michigan

Peer Reviewers for the intermediate-duration inhalation MRL:

1. Mary Beth Genter, Ph.D., DABT; Professor, Department of Environmental Health, University of Cincinnati; Cincinnati, Ohio
2. Thomas E. McKone, Ph.D.; Energy Analysis and Environmental Impacts Division, Lawrence Berkeley National Laboratory; Berkeley California
3. Ivan Rusyn, M.D., Ph.D.; Professor; Department of Veterinary Integrative Biosciences, College of Vet Medicine & Biomedical Sciences, Texas A&M University; College Station, Texas

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.