# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding ethylene oxide in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for ethylene oxide.

Table 7-1 Regulations and Guidelines Applicable to Ethylene Oxide

Agency | Description | Information | Reference
Air
EPA | RfC | Not assessed | EPA 2016, IRIS 2021
OEHHA | RfC (chronic) | 30 µg/m^3^ (18 ppb) | OEHHA 2008
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018d
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | Not assessed | EPA 2016, IRIS 2021
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances added to food | No longer FEMA GRAS^a^ | FDA 2021
Cancer
HHS | Carcinogenicity classification | Known to be a human carcinogen | NTP 2016
EPA | Carcinogenicity classification | Carcinogenic to humans | EPA 2016
EPA | Inhalation unit risk (lifetime-based for lymphoid and female breast cancer combined) | 5.0×10^-3^ per µg/m^3^ (9.1×10^-3^ per ppb) for environmental ethylene oxide exposures up to about 40 µg/m^3^ (20 ppb) | EPA 2016
EPA | Inhalation unit risk (adult-based for lymphoid and female breast cancer combined) | 3.0×10^-3^ per µg/m^3^ (5.5×10^-3^ per ppb) for environmental ethylene oxide exposures up to about 40 µg/m^3^ (20 ppb) | EPA 2016
IARC | Carcinogenicity classification | Group 1^b^ | IARC 2012, IARC 2021
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 1 ppm; (1.83 mg/m^3^) | OSHA 2021a, 2021b, 2021c
OSHA | Excursion limit^c^ (15-minute) for general industry, shipyards, and construction | 5 ppm; (9.15 mg/m^3^) | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | <0.1 ppm^d^; (<0.183 mg/m^3^) | NIOSH 2019
NIOSH | Ceiling REL (10-minute/day) | 5 ppm; (9.15 mg/m^3^) | NIOSH 2019
NIOSH | IDLH | 800 ppm; (1,464 mg/m^3^) | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air^e^ | | EPA 2018e
EPA | AEGL 2^f^
EPA | 10-minute | 80 ppm; (146.4 mg/m^3^)
EPA | 30-minute | 80 ppm; (146.4 mg/m^3^)
EPA | 60-minute | 45 ppm; (82.35 mg/m^3^)
EPA | 4-hour | 14 ppm; (25.62 mg/m^3^)
EPA | 8-hour | 7.9 ppm; (14.46 mg/m^3^)
EPA | AEGL 3^f^
EPA | 10-minute | 360 ppm; (658.8 mg/m^3^)
EPA | 30-minute | 360 ppm; (658.8 mg/m^3^)
EPA | 60-minute | 200 ppm; (366 mg/m^3^)
EPA | 4-hour | 63 ppm; (115.29 mg/m^3^)
EPA | 8-hour | 35 ppm; (64.05 mg/m^3^)
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^g^ | 5 ppm (9.15 mg/m^3^)
DOE | PAC-2^g^ | 45 ppm (82.35 mg/m^3^)
DOE | PAC-3^g^ | 200 ppm (366 mg/m^3^)

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group 1: carcinogenic to humans.

c Exposure not to exceed 5 ppm as averaged over a sampling period of 15 minutes.

d Potential occupational carcinogen.

e No recommendations for AEGL 1 due to insufficient data.

f Definitions of AEGL terminology are available from U.S. Environmental Protection Agency (EPA 2018f).

g Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline level; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FAO = Food and Agricultural Organization of the United Nations; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OEHHA = California’s Office of Environmental Health Hazard Assessment; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization