# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Ethylene oxide is both a manmade substance and a natural substance produced in the body via oxidation of absorbed or endogenously produced ethylene during normal oxidation processes.

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for ethylene oxide.

Table 4-1 Chemical Identity of Ethylene Oxide

Characteristic | Information | Reference
Chemical name | Ethylene oxide | NLM 2021
Synonym(s) and registered trade name(s) | Oxirane; dihydro-oxirane; dimethylene oxide; epoxyethane; ETO; Anprolene; Oxyfume; T-Gas; 1,2-epoxyethane; ethene oxide; diethylene oxide; E.O.; oxane; oxidoethane | NLM 2021; Parod 2014; WHO 2003
Chemical formula | C_2_H_4_O | EPA 2017b
Chemical structure | Ethylene Oxide Chemical structure
CAS Registry Number | 75-21-8 | WHO 2003

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Ethylene oxide is a colorless, flammable gas. It is highly soluble in water (1×10^6^ mg/L at 20°C) and possesses a high vapor pressure (1.095×10^3^ mm Hg at 20°C).

Table 4-2 lists important physical and chemical properties of ethylene oxide.

Table 4-2 Physical and Chemical Properties of Ethylene Oxide

Property | Information | Reference
Molecular weight | 44.05 g/mol | WHO 2003
Color | Colorless | WHO 2003
Physical state | Gas | NIOSH 2007
Melting point | -111.7°C | NLM 2021
Boiling point | 51°F (10.6°C) | NIOSH 2016
Density at 10°C | 0.8824 | NLM 2021; Weast 1985
Odor | Sweet, olefinic; ether-like | NIOSH 2007; Verschueren 1983
Odor threshold:
Water | 140 mg/L | Amoore and Hautala 1983
Air | 787 mg/m^3^ (432.85 ppm) | Amoore and Hautala 1983
Solubility:
Water at 20°C | 1×10^6^ mg/L | EPA 2017b
Organic solvents | Soluble in alcohol, ether, acetone, benzene | EPA 2017b
Partition coefficients:
Log K_ow_ | -0.22 | EPA 2017b
Log K_oc_ | 1.204 | WHO 2003
Vapor pressure at 20°C | 1.095×10^3^ mm Hg | EPA 2017b
Henry’s law constant at 25°C | 1.48×10^-4^ atm-m^3^/mol | NLM 2021
Autoignition temperature | 429°C | NLM 2021
Flashpoint | <-18°C (open cup) | NLM 2021
Flammability limits | Lower: 3.0%; Upper: 100% | NLM 2021
Conversion factors at 20°C and 101.3 kPa | 1 ppm=1.83 mg/m^3^; 1 mg/m^3^=0.55 ppm | WHO 2003
Explosive limits | Lower: 3.0%; Upper: 100% | NLM 2021