# APPENDIX G ACRONYMS, ABBREVIATIONS, AND SYMBOLS

AAPCC: American Association of Poison Control Centers
ACGIH: American Conference of Governmental Industrial Hygienists
ACOEM: American College of Occupational and Environmental Medicine
ACMT: American College of Medical Toxicology
ADI: acceptable daily intake
ADME: absorption, distribution, metabolism, and excretion
AEGL: Acute Exposure Guideline Level
AIC: Akaike’s information criterion
AIHA: American Industrial Hygiene Association
ALT: alanine aminotransferase
AOEC: Association of Occupational and Environmental Clinics
AP: alkaline phosphatase
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AWQC: Ambient Water Quality Criteria
BCF: bioconcentration factor
BMD/C: benchmark dose or benchmark concentration
BMD_X_: dose that produces a X% change in response rate of an adverse effect
BMDL_X_: 95% lower confidence limit on the BMD_X_
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
C: centigrade
CAA: Clean Air Act
CAS: Chemical Abstract Services
CDC: Centers for Disease Control and Prevention
CEL: cancer effect level
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
Ci: curie
CI: confidence interval
cm: centimeter
CPSC: Consumer Products Safety Commission
CWA: Clean Water Act
DNA: deoxyribonucleic acid
DOD: Department of Defense
DOE: Department of Energy
DWEL: drinking water exposure level
EAFUS: Everything Added to Food in the United States
ECG/EKG: electrocardiogram
EEG: electroencephalogram
EPA: Environmental Protection Agency
ERPG: emergency response planning guidelines
F: Fahrenheit
F1: first-filial generation
FDA: Food and Drug Administration
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
FR: Federal Register
FSH: follicle stimulating hormone
g: gram
GC: gas chromatography
gd: gestational day
GGT: γ-glutamyl transferase
GRAS: generally recognized as safe
HEC: human equivalent concentration
HED: human equivalent dose
HHS: Department of Health and Human Services
HPLC: high-performance liquid chromatography
HSDB: Hazardous Substance Data Bank
IARC: International Agency for Research on Cancer
IDLH: immediately dangerous to life and health
IRIS: Integrated Risk Information System
Kd: adsorption ratio
kg: kilogram
kkg: kilokilogram; 1 kilokilogram is equivalent to 1,000 kilograms and 1 metric ton
K_oc_: organic carbon partition coefficient
K_ow_: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_50_: lethal concentration, 50% kill
LC_Lo_: lethal concentration, low
LD_50_: lethal dose, 50% kill
LD_Lo_: lethal dose, low
LDH: lactic dehydrogenase
LH: luteinizing hormone
LOAEL: lowest-observed-adverse-effect level
LSE: Level of Significant Exposure
LT_50_: lethal time, 50% kill
m: meter
mCi: millicurie
MCL: maximum contaminant level
MCLG: maximum contaminant level goal
MF: modifying factor
mg: milligram
mL: milliliter
mm: millimeter
mmHg: millimeters of mercury
mmol: millimole
MRL: Minimal Risk Level
MS: mass spectrometry
MSHA: Mine Safety and Health Administration
Mt: metric ton
NAAQS: National Ambient Air Quality Standard
NAS: National Academy of Science
NCEH: National Center for Environmental Health
ND: not detected
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NLM: National Library of Medicine
nm: nanometer
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NPL: National Priorities List
NR: not reported
NRC: National Research Council
NS: not specified
NTP: National Toxicology Program
OR: odds ratio
OSHA: Occupational Safety and Health Administration
PAC: Protective Action Criteria
PAH: polycyclic aromatic hydrocarbon
PBPD: physiologically based pharmacodynamic
PBPK: physiologically based pharmacokinetic
PEHSU: Pediatric Environmental Health Specialty Unit
PEL: permissible exposure limit
PEL-C: permissible exposure limit-ceiling value
pg: picogram
PND: postnatal day
POD: point of departure
ppb: parts per billion
ppbv: parts per billion by volume
ppm: parts per million
ppt: parts per trillion
REL: recommended exposure limit
REL-C: recommended exposure limit-ceiling value
RfC: reference concentration
RfD: reference dose
RNA: ribonucleic acid
SARA: Superfund Amendments and Reauthorization Act
SCE: sister chromatid exchange
SD: standard deviation SE standard error
SGOT: serum glutamic oxaloacetic transaminase (same as aspartate aminotransferase or AST)
SGPT: serum glutamic pyruvic transaminase (same as alanine aminotransferase or ALT)
SIC: standard industrial classification
SLOAEL: serious lowest-observed-adverse-effect level
SMR: standardized mortality ratio
sRBC: sheep red blood cell
STEL: short term exposure limit
TLV: threshold limit value
TLV-C: threshold limit value-ceiling value
TRI: Toxics Release Inventory
TSCA: Toxic Substances Control Act
TWA: time-weighted average
UF: uncertainty factor
U.S.: United States
USDA: United States Department of Agriculture
USGS: United States Geological Survey
USNRC: U.S. Nuclear Regulatory Commission
VOC: volatile organic compound
WBC: white blood cell
WHO: World Health Organization

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
γ: gamma
δ: delta
μm: micrometer
μg: microgram
q1*: cancer slope factor
–: negative
+: positive
(+): weakly positive result
(–): weakly negative result