# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR ETHYLENE OXIDE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to ethylene oxide.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for ethylene oxide. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of ethylene oxide have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of ethylene oxide are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for ethylene oxide released for public comment in 2020; thus, the literature search was restricted to studies published between Month YEAR and Month YEAR. The following main databases were searched in January 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for ethylene oxide. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to ethylene oxide were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2021 | (75-21-8 [rn] AND (((“ethylene oxide/toxicity”[mh] OR “ethylene oxide/adverse effects”[mh] OR “ethylene oxide/poisoning”[mh] OR “ethylene oxide/pharmacokinetics”[mh] OR “ethylene oxide/blood”[mh] OR “ethylene oxide/cerebrospinal fluid”[mh] OR “ethylene oxide/urine”[mh] OR “ethylene oxide/antagonists & inhibitors”[mh]) OR (“ethylene oxide”[mh] AND (“environmental exposure”[mh] OR “chemically induced”[sh])) OR (“ethylene oxide”[mh] AND toxicokinetics[mh:noexp]) OR (“ethylene oxide”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“ethylene oxide”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“ethylene oxide/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“ethylene oxide”[mh] AND cancer[sb]) OR (“ethylene oxide/pharmacology”[majr])) AND (2018:3000[dp] OR 2018:3000[mhda] OR 2018:3000[crdt] OR 2018:3000[edat]))) OR (((“1,2-Epoxyethane”[tw] OR “Amprolene”[tw] OR “Anprolene”[tw] OR “dihydrooxirene”[tw] OR “Epoxyethane”[tw] OR “Ethene oxide”[tw] OR “ethylene oxide”[tw] OR “Ethyleneoxy”[tw] OR “Ethylenoxid”[tw] OR “Merpol”[tw] OR “Oxacyclopropane”[tw] OR “Oxane”[tw] OR “Oxidoethane”[tw] OR “Oxiran”[tw] OR “Oxirane”[tw] OR “Oxyfume”[tw] OR “Anproline”[tw] OR “Dimethylene oxide”[tw] OR “Emulsifier-Ethylene oxide”[tw] OR “Ethylene oxide-ionene copolymer”[tw] OR “Mirror Ox”[tw] OR “1,2,3,4-tetrahydro-1,1,6-trimethyl-Naphthalene polymer with oxirane”[tw] OR “Naphthalene, 1,2,3,4-tetrahydro-1,1,6-trimethyl-, polymer with oxirane”[tw] OR “Oxirane, polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene”[tw] OR “polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene oxirane”[tw] OR “Oxirene, dihydro-”[tw] OR “Oxyfume 12”[tw] OR “Oxyfume 2002”[tw]) NOT medline[sb]) AND (2018:3000[crdt] OR 2018:3000[edat] OR 2018:3000[dp]))
NTRL
01/2021 | “1,2-Epoxyethane” OR “Amprolene” OR “Anprolene” OR “dihydrooxirene” OR “Epoxyethane” OR “Ethene oxide” OR “ethylene oxide” OR “Ethyleneoxy” OR “Ethylenoxid” OR “Merpol” OR “Oxacyclopropane” OR “Oxane” OR “Oxidoethane” OR “Oxiran” OR “Oxirane” OR “Oxyfume”; “Anproline” OR “Dimethylene oxide” OR “Emulsifier-Ethylene oxide” OR “Ethylene oxide-ionene copolymer” OR “Mirror Ox” OR “1,2,3,4-tetrahydro-1,1,6-trimethyl-Naphthalene polymer with oxirane” OR “Naphthalene, 1,2,3,4-tetrahydro-1,1,6-trimethyl-, polymer with oxirane” OR “Oxirane, polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene” OR “polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene oxirane” OR “Oxirene, dihydro-” OR “Oxyfume 12” OR “Oxyfume 2002”
Toxcenter
01/2021 | FILE ‘TOXCENTER’ ENTERED AT 13:04:37 ON 26 JAN 2021; CHARGED TO COST=EH038.06.01.LB.03; L1 10178 SEA 75-21-8; L2 9971 SEA L1 NOT TSCATS/FS; L3 6793 SEA L1 NOT PATENT/DT; L4 6586 SEA L2 NOT PATENT/DT; L5 283 SEA L4 AND PY>=2018; ACTIVATE TOXQUERY/Q; -------; L6 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L7 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L8 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L9 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L10 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L11 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L12 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L13 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L14 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L15 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L16 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L17 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L18 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L19 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L20 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L21 QUE (ENDOCRIN? AND DISRUPT?); L22 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L23 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L24 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L25 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L26 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L27 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L28 QUE (NEPHROTOX? OR HEPATOTOX?); L29 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L30 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L31 QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30; L32 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L33 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L34 QUE L31 OR L32 OR L33; L35 QUE (NONHUMAN MAMMALS)/ORGN; L36 QUE L34 OR L35; L37 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L38 QUE L36 OR L37; -------; L39 194 SEA L5 AND L36; L40 191 SEA L5 AND L31; L41 27 SEA L40 AND MEDLINE/FS; L42 29 SEA L40 AND BIOSIS/FS; L43 132 SEA L40 AND CAPLUS/FS; L44 3 SEA L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L45 169 DUP REM L41 L42 L44 L43 (22 DUPLICATES REMOVED); L*** DEL 27 S L40 AND MEDLINE/FS; L*** DEL 27 S L40 AND MEDLINE/FS; L46 27 SEA L45; L*** DEL 29 S L40 AND BIOSIS/FS; L*** DEL 29 S L40 AND BIOSIS/FS; L47 22 SEA L45; L*** DEL 132 S L40 AND CAPLUS/FS; L*** DEL 132 S L40 AND CAPLUS/FS; L48 117 SEA L45; L*** DEL 3 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 3 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L49 3 SEA L45; L50 142 SEA (L46 OR L47 OR L48 OR L49) NOT MEDLINE/FS D SCAN L50

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
01/2021 | Compounds searched: 75-21-8
NTP
01/2021 | Limited to 2010 – present; “Epoxyethane” “Ethene oxide” “ethylene oxide” “Ethyleneoxy”; “Oxidoethane” “Oxiran” “Oxirane” “Oxyfume”; “75-21-8”; “1,2-Epoxyethane” “Amprolene” “Anprolene” “dihydrooxirene”; “Ethylenoxid” “Merpol” “Oxacyclopropane” “Oxane”
Regulations.gov
01/2021 | Documents limited to: date 2018-Present; Notice; U.S. EPA; 75-21-8; Ethylene oxide; Docket limited to: U.S. EPA; 75-21-8; Ethylene oxide”
NIH RePORTER
07/2021 | Active projects,; Text Search: “1,2-Epoxyethane” OR “Amprolene” OR “Anprolene” OR “dihydrooxirene” OR “Epoxyethane” OR “Ethene oxide” OR “ethylene oxide” OR “Ethyleneoxy” OR “Ethylenoxid” OR “Merpol” OR “Oxacyclopropane” OR “Oxane” OR “Oxidoethane” OR “Oxiran” OR “Oxirane” OR “Oxyfume” OR “Anproline” OR “Dimethylene oxide” OR “Emulsifier-Ethylene oxide” OR “Ethylene oxide-ionene copolymer” OR “Mirror Ox” OR “1,2,3,4-tetrahydro-1,1,6-trimethyl-Naphthalene polymer with oxirane” OR “Naphthalene, 1,2,3,4-tetrahydro-1,1,6-trimethyl-, polymer with oxirane” OR “Oxirane, polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene” OR “polymer with 1,2,3,4-tetrahydro-1,1,6-trimethylnaphthalene oxirane” OR “Oxirene, dihydro-” OR “Oxyfume 12” OR “Oxyfume 2002” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 934
- Number of records identified from other strategies: 22
- Total number of records to undergo literature screening: 956

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on ethylene oxide:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 956
- Number of studies considered relevant and moved to the next step: 47

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 47
- Number of studies cited in the pre-public draft of the toxicological profile: 346
- Total number of studies cited in the profile: 369

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 January 2021 Literature Search Results and Screen for Ethylene Oxide