# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene Oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.4 ppm
Critical Effect: | Depressed fetal weight
Reference: | Snellings et al. 1982a
Point of Departure: | BMCL_RD05_ of 45.50 ppm (BMCL_HEC_ of 11.38 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 11
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.4 ppm has been derived for ethylene oxide based on depressed mean male fetal weight following exposure of pregnant Fischer 344 rats to ethylene oxide vapor for 6 hours/day during gestation days 6–15 (Snellings et al. 1982a). The BMCL_05_ of 45.50 ppm was adjusted for intermittent exposure and converted to a human equivalent concentration (BMCL_HEC_) of 11.38 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response human data are available. Two rat studies were designed to evaluate acute lethality following single 1- or 4-hour exposure (Jacobson et al. 1956; Snellings et al. 2011). NTP (1987) evaluated the effects of repeated inhalation exposure of rats and mice for 2 weeks or up to 2 weeks during 14-week studies. Several studies were designed to evaluate the effects of maternal exposure during periods of gestation (Neeper-Bradley and Kubena 1993; NIOSH 1982; Rutledge and Generoso 1989; Saillenfait et al. 1996; Snellings et al. 1982a).

Selected results from the studies that evaluated sublethal effects (potential candidates for MRL derivation) are summarized in Table A-1. Several studies were considered inadequate for the purpose of deriving an acute-duration inhalation MRL for ethylene oxide. NTP (1987) reported a respiratory effect (rhinitis) at an exposure level (71.4 ppm) resulting in 90% mortality during 2 weeks of repeated exposures. The study of Rutledge and Generoso (1989) employed only a single high ethylene oxide exposure concentration (1,200 ppm) for an exposure period of 1.5 hours. The studies of Saillenfait et al. (1996) employed short exposure durations (30 minutes/day or three 30-minute periods/day).

In two developmental toxicity studies, pregnant rats were exposed to ethylene oxide vapors for 6 hours/day during gestation days 6–15. The studies reported fetal weight data as mean of litter means. Sprague-Dawley rats were used in the study of Neeper-Bradley and Kubena (1993); the study identified a NOAEL of 50 ppm and a LOAEL of 125 ppm for 5% depressed mean fetal weight. Fischer 344 rats were used in the study of Snellings et al. (1982a); the study identified a NOAEL of 33 ppm and a LOAEL of 100 ppm for up to 9% depressed mean fetal weight.

Table A-1 Summary of Selected NOAELs and LOAELs from Acute-Duration Studies in Animals Exposed to Ethylene Oxide by Inhalation

Species | Exposure scenario | NOAEL (ppm) | LOAEL (ppm) | NOAEL_ADJ_^a^ (ppm) | LOAEL_ADJ_^a^ (ppm) | Effect | Reference
Respiratory effects
B6C3F1 mouse | Up to 2 weeks during a; 14-week study; 5 days/week; 6 hours/day | ND | 400^b^ | ND | 71.4 | Rhinitis | NTP 1987
Developmental effects
Fischer 344 rat | GDs 6–15; 6 hours/day | 33 F | 100 F | 8.3 F | 25 F | Up to 9% depressed mean fetal weight | Snellings et al. 1982a
Sprague-Dawley rat | GDs 6–15; 30 minutes/day | 800 F | 1,200 F | 16.7 | 25 F | Increased incidence of dilation in renal pelvis and ureter of fetuses | Saillenfait et al. 1996
Sprague-Dawley rat | GDs 6–15; 6 hours/day | 50 | 125 | 12.5 | 31.3 | 5% depressed mean fetal weight | Neeper-Bradley and Kubena 1993
Sprague-Dawley rat | GDs 7–16; 7 hours/day | ND | 150 F | ND | 43.8 F | 5–6% depressed mean fetal weight; decreased crown-rump length; delayed ossification (skull, sternebrae) | NIOSH 1982
Sprague-Dawley rat | GDs 6–15; 3×30 minutes/day | ND | 800 F | ND | 50 F | 4–7% depressed mean fetal weight at maternally toxic exposure level | Saillenfait et al. 1996
Hybrid mouse | Once for 1.5 hours | ND | 1,200 F | ND | 75 F | Selected fetal defects (mostly hydrops and eye defects) | Rutledge and Generoso 1989

a Duration-adjusted from intermittent exposure to a continuous exposure scenario.

b Lethal exposure level.

ADJ = adjusted; F = female(s); GD = gestation day; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The mean fetal weight data in the developmental toxicity study of Fischer 344 maternal rats (Snellings et al. 1982a) were selected to represent the critical effect of acute-duration inhalation exposure to ethylene oxide because the fetal weight data represent the lowest LOAEL (100 ppm); the corresponding NOAEL was 33 ppm. As shown in Table A-1, duration adjustment (to account for a continuous exposure scenario) of NOAELs and LOAELs from the various studies did not result in a more appropriate principal study or critical effect.

Summary of the Principal Study:

Snellings WM, Maronpot RR, Zelenak JP, . 1982a. Teratology study in Fischer 344 rats exposed to ethylene oxide by inhalation. Toxicol Appl Pharmacol 64:476–481.7135397

Groups of 22 pregnant Fischer 344 rats were exposed to 0, 0, 10, 33, or 100 ppm ethylene oxide 6 hours/day on gestation days 6–15 and sacrificed on gestation day 20. Parameters used to assess toxicity included number of implantation sites, viable fetuses, dead fetuses, early resorption sites, and late resorption sites, number of corpora lutea, fetal body weight, sex, crown-to-rump length, external fetal abnormalities, and internal and skeletal abnormalities in both control and 100 ppm groups (examined in 10 and 33 ppm groups if effects were noted at 100 ppm).

No overt signs of toxicity were observed in the dams. No alterations in preimplantation loss or embryo or fetal resorptions were observed. Significant decreases in fetal body weight were observed at 100 ppm (approximately 6–9% in males and 3–6% in females), but there were no differences in crown-rump length. An increase in the occurrence of vertebrae ossification variations was observed at 100 ppm, but the incidence was not significantly different from controls. No other developmental alterations were observed. The fetal weight data are presented in Table A-2. Although there are no established guidelines as to what minimal change in a continuous endpoint such as body weight is biologically significant, a 10% change is generally used for adult body weight. However, because fetal or neonatal organisms may be more susceptible than adults, a ≥5% decrease in fetal body weight relative to controls was selected to represent an adverse effect.

Table A-2 Fetal Weight Data (Mean of Litter Means) for Fetuses of Maternal Fischer 344 Rats Exposed to Ethylene Oxide Vapor for 6 Hours/Day During Gestation Days 6–15

Number of litters | Ethylene oxide exposure level (ppm)
Number of litters | 0 (control I) | 0 (control II) | 10 | 33 | 100
Number of litters | 21 | 17 | 20 | 21 | 19
Mean fetal weight (g) | M: 3.4±0.4^a^; F: 3.1±0.3 | M: 3.3±0.2; F: 3.0±0.2 | M: 3.3±0.3; F: 3.0±0.3 | M: 3.3±0.3; F: 3.1±0.3 | M: 3.1^b^±0.2; F: 2.9^b^±0.1

a Mean of litter means ± standard deviation.

b Significantly different from each sex-matched control group by Duncan’s multiple range test (p<0.05).

F = female; M = male

Source: Snellings et al. 1982a

Selection of the Point of Departure for the MRL: A benchmark dose (BMD) approach was applied to derive the acute-duration inhalation MRL for ethylene oxide. Fetal body weight data from Snellings et al. (1982a; Table A-2) were fit to all available continuous variable models in the EPA Benchmark Dose Software (BMDS, version 3.2) using a benchmark response (BMR) of 5% relative deviation from control and the assumption of constant variance. However, continuous Hill models were not considered viable because the model has five parameters, requiring a minimum of six data points (including control), and these data sets have only four or five data points. For remaining models, adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value ≥0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among models providing adequate fit to the data, the lowest BMCL was selected as the point of departure (POD) when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

BMD modeling results for male fetal weight data reported by Snellings et al. (1982a; see Table A-2) are summarized in Table A-3. Data were a fit to constant variance. Among models providing viable results, the 4-degree Polynomial model-predicted BMCL_RD05_ of 45.50 ppm was selected as a potential POD because it provided the lowest AIC.

Table A-3 Results from BMD Analysis (Constant Variance) of Male Fetal Weight Following Maternal Exposure of Fischer 344 Rats to Ethylene Oxide Vapor for 6 Hours/Day During Gestation Days 6–15 (Snellings et al. 1982a)

Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 67.70 | 43.83 | 0.81 | 40.98 | 0.47 | -0.13
Exponential (model 3)^d^ | 74.58 | 44.00 | 0.55 | 42.91 | 0.22 | -0.03
Exponential (model 4)^d^ | 67.69 | 43.83 | 0.81 | 40.98 | 0.47 | -0.13
Exponential (model 5)^d^ | 73.93 | 44.00 | 0.55 | 42.91 | 0.24 | -0.04
Polynomial (2-degree)^e^ | 76.38 | 45.43 | 0.58 | 42.86 | 0.19 | -0.02
Polynomial (3-degree)^e^ | 79.24 | 45.51 | 0.87 | 40.84 | 0.15 | -0.01
Polynomial (4-degree) ^e^ ^,^ ^f^ | 81.48 | 45.50 | 0.87 | 40.83 | 0.14 | -0.002
Linear^e^ | 68.39 | 45.14 | 0.82 | 40.96 | 0.45 | -0.11
Power | 74.61 | 54.00 | 0.56 | 42.90 | 0.22 | -0.03

a BMCLs <10 times the lowest non-zero dose and their corresponding BMCs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. Using constant variance, all models provided adequate fit. BMCLs for all models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (4-degree Polynominal).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD05 = dose associated with a 5% relative deviation)

Table A-4 summarizes the results of BMD modeling for female fetal weight data reported by Snellings et al. (1982a; see Table A-2). None of the models provided adequate fit to the data using constant variance. Therefore, the data were fit to all models using nonconstant variance. The Power model and Polynomial models (2-, 3-, and 4-degree) provided viable results. Among these models, the 4-degree Polynomial model-predicted BMCL_RD05_ of 87.00 ppm was selected as a potential POD because the model provided the lowest AIC.

Table A-4 Results from BMD Analysis (Nonconstant Variance) of Female Fetal Weight Following Maternal Exposure of Fischer 344 Rats to Ethylene Oxide Vapor for 6 Hours/Day During Gestation Days 6–15 (Snellings et al. 1982a)

Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | | | 0.01 | 5.97 | 1.46 | 0.41
Exponential (model 3)^d^ | | | 0.03 | 2.00 | 0.40 | 0.93
Exponential (model 4)^d^ | | | 0.01 | 5.97 | 1.46 | 0.41
Exponential (model 5)^d^ | | | 0.03 | 2.00 | 0.40 | 0.93
Polynomial (2-degree)^e^ | 97.62 | 82.74 | 0.31 | -2.54 | 1.00 | -0.02
Polynomial (3-degree)^e^ | 96.02 | 84.98 | 0.68 | -5.37 | 0.68 | 0.28
Polynomial (4-degree) ^e^ ^,^ ^f^ | 99.07 | 87.00 | 0.83 | -6.00 | 0.75 | 0.07
Linear^e^ | | | 0.01 | 4.41 | 1.59 | -0.23
Power | 99.98 | 98.35 | 0.39 | -2.14 | 0.76 | 0.003

a BMCLs <10 times the lowest non-zero dose and their corresponding BMCs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. Using nonconstant variance, the polynomial and power models provided adequate fit to the data. BMCLs for these models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (4-degree Polynomial).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD05 = dose associated with a 5% relative deviation)

Fetal weight data (per litter) reported by Neeper-Bradley and Kubena (1993; see Table A-5) were also modeled for comparison. Table A-6 summarize the results of BMD modeling for this data set. Data were a fit to constant variance. All models provided adequate fit to the data. The Exponential model 3 was selected as the best-fitting model (lowest AIC) and provided a BMCL_RD05_ of 92.09 ppm.

Table A-5 Fetal Weight per Litter Following Maternal Exposure of Sprague-Dawley Rats to Ethylene Oxide Vapor for 6 Hours/Day on Gestation Days 6–15

| Ethylene oxide concentration (ppm)
| 0 | 50 | 125 | 225
Number of litters | 23 | 20 | 20 | 24
Fetal weight per litter (g) | 5.161±0.2480^a^ | 4.972±0.2766^b^ | 4.891±0.2745^b^ | 4.644±0.2899^c^

a Mean ± standard deviation.

b Significantly different from control group by t- test (p<0.05).

c Significantly different from control group by t- test (p<0.01).

Source: Neeper-Bradley and Kubena 1993

Table A-6 Fetal Weight per Litter Following Maternal Exposure of Sprague-Dawley Rats to Ethylene Oxide Vapor for 6 Hours/Day on Gestation Days 6–15 (Neeper-Bradley and Kubena 1993)

Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD05_^a^ | BMCL_RD05_^a^ | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 115.38 | 92.07 | 0.54 | 23.92 | -0.88 | 0.52
Exponential (model 3) ^e^ | 115.38 | 92.09 | 0.54 | 23.92 | -0.88 | 0.52
Exponential (model 4)^d^ | 112.35 | 59.62 | 0.27 | 25.91 | -0.85 | 0.58
Exponential (model 5)^d^ | 115.38 | 59.50 | 0.27 | 25.92 | -0.88 | 0.52
Polynomial (2-degree)^f^ | 118.32 | 95.58 | 0.53 | 23.95 | -0.91 | 0.46
Polynomial (3-degree)^f^ | 118.32 | 95.58 | 0.53 | 23.95 | -0.91 | 0.46
Linear^f^ | 118.32 | 95.58 | 0.53 | 23.95 | -0.91 | 0.46
Power^d^ | 118.32 | 95.59 | 0.53 | 23.95 | -0.91 | 0.46

a BMCLs <10 times the lowest non-zero dose and their corresponding BMCs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. Using constant variance, all models provided adequate fit. BMCLs for all models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential model 3).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD05 = dose associated with a 5% relative deviation)

Potential PODs for deriving an acute-duration inhalation MRL for ethylene oxide include:

- BMCL_RD05_ of 92.09 ppm from the fetal weight data of Neeper-Bradley and Kubena (1993)
- BMCL_RD05_ of 87.00 ppm from the female fetal weight data of Snellings et al. (1982a)
- BMCL_RD05_ of 45.50 ppm from the male fetal weight data of Snellings et al. (1982a)

The BMCL_RD05_ of 45.50 ppm from the male fetal weight data of Snellings et al. (1982a) was selected as the POD for deriving an acute-duration inhalation MRL for ethylene oxide because it represents the most conservative (health-protective) POD. The 4-degree Polynomial model fit to the male fetal weight data is presented in Figure A-1.

Figure A-1 Fit of 4-Degree Polynominal Model to Data on Male Fetal Weight Following Maternal Exposure of Fischer 344 Rats to Ethylene Oxide Vapor

Calculations

Intermittent Exposure: The BMCL_RD05_ of 45.50 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

BMCL_ADJ_ = BMCL_RD05_ of 45.50 ppm × ( 6 hours / 24 hours ) = 11.38 ppm

Human Equivalent Concentration: A PBPK modeling approach was initially considered to calculate a human equivalent to the rat BMCL_ADJ_. However, a PBPK modeling approach was rejected due to a lack of experimental data regarding the proper dose metric (proximate toxicant) for ethylene oxide-induced developmental toxicity. Therefore, a human equivalent concentration was calculated by multiplying the duration adjusted BMCL by the regional gas dose ratio (RGDR). The RGDR for extrarespiratory tract effects is the ratio of animal to human blood:gas partition coefficients:

BMCL_HEC_ = BMCL_ADJ_ × RGDR_ER_ BMCL_HEC_ = BMCL_ADJ_ × ( [ H_b/g_ ]_A_ / [ H_b/g_ ]_H_ )

[H_b/g_]_A_ = animal blood/air partition coefficient = 64.1 for rats (Krishnan et al. 1992)

[H_b/g_]_H_ = human blood/air partition coefficient = 61 for humans (Csanady et al. 2000)

A default value of 1 is used for the ratio of blood/air partition coefficients because the animal value is greater than the human value.

BMCL_HEC_ = 11.38 ppm × 1 = 11.38 ppm

Uncertainty Factor: The BMCL_HEC_ of 11.38 ppm was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans using dosimetric adjustment
- 10 for human variability

MRL = BMCL_HEC_ ÷ UF MRL = 11.38 ppm ÷ ( 3 × 10 ) = 0.379 ppm ≈ 0.4 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Other acute-duration developmental toxicity studies in rats identified fetal body weight effects as well (Neeper-Bradley and Kubena 1993; NIOSH 1982; Saillenfait et al. 1996), although LOAELs were higher than the LOAEL of Snellings et al. (1982a). Reduced fetal body weight was also observed in rats exposed to inhaled ethylene oxide for intermediate exposure durations (EPA 1994; NIOSH 1982)

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene Oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.07 ppm
Critical Effect: | Decreased pup body weight
Reference: | EPA 1994
Point of Departure: | NOAEL of 10 ppm (NOAEL_HEC_ of 2.1ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 22
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.07 ppm has been derived based on decreased body weight in F1 male pups on postnatal day (PND) 21 in CD rats exposed to ethylene oxide vapor for 6 hours/day, 5.85 days/week in a 2-generation reproduction study (EPA 1994). The MRL is based on a NOAEL of 10 ppm that was adjusted to continuous exposure and converted to a human equivalent concentration (NOAEL_HEC_) of 2.1 ppm, divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response human data are available. Case studies of workers have reported a number of neurological effects including headache, neuropathy, impaired hand-eye coordination, hand numbness, cognitive dysfunction, and memory loss (Brashear et al. 1996; Crystal et al. 1988; Dretchen et al. 1992; Estrin et al. 1987; Finelli et al. 1983; Kuzuhara et al. 1983; Salinas et al. 1981; Schröder et al. 1985; Zampollo et al. 1984). These effects were seen at estimated average exposure levels as low as 3 ppm; however, short-term exposures may have been as high as 700 ppm for some of these workers. These case studies are insufficient to establish a causal relationship between exposure to ethylene oxide and neurological effects in humans.

Several animal studies evaluated sublethal effects of intermediate-duration inhalation exposure in laboratory animals (EPA 1994, 2005b; Fujishiro et al. 1990; Matsuoka et al. 1990; Mori et al. 1991a, 1991b; NIOSH 1982; NTP 1987; Ohnishi et al. 1985, 1986; Snellings et al. 1982b, 1984a). Adverse effects were observed in the respiratory, hematological, renal, neurological, and reproductive systems, and in the developing fetus; the most sensitive NOAELs and LOAELs for these effects are summarized in Table A-7. EPA (1994) reported the lowest LOAEL of 33 ppm, with a NOAEL of 10 ppm, for developmental effects (decreased PND pup weight in F1 males) and reproductive effects (increased post-implantation loss in F0 rats). For other systems, the lowest LOAELs were as follows: 100 ppm for renal effects (renal tubular degeneration) (NTP 1987); 200 ppm for respiratory effects (rhinitis) (NTP 1987); and 200 ppm for neurological effects (decreased hindlimb strength) (EPA 2005b); and 250 ppm for hematological effects (decreases in hemoglobin, erythrocyte count, packed cell volume, and/or mean corpuscular hemoglobin) (Snellings et al. 1984a)

Table A-7 Summary of Selected NOAELs and LOAELs from Intermediate-Duration Studies in Animals Exposed to Ethylene Oxide by Inhalation

Species | Exposure scenario | NOAEL (ppm) | LOAEL (ppm) | NOAEL_ADJ_^a^ (ppm) | LOAEL_ADJ_^a^ (ppm) | System: effect | Reference
CD rat | 10 weeks premating; (6 hours/day, 5 days/week) and during mating, gestation, and lactation (6 hours/day, 7 days/week) | 10 | 33 | 2.1^b^ | 6.89^b^ | Developmental: Decreased pup body weight in F1 males on PND 21 | EPA 1994
CD rat | 10 weeks premating; (6 hours/day, 5 days/week) and during mating, gestation, and lactation (6 hours/day, 7 days/week) | 10 | 33 (SLOAEL) | 2.1^b^ | 6.89^b^ | Reproductive: Increased post-implantation loss in F0 rats | EPA 1994
B6C3F1 mouse | Up to 14 weeks (6 hours/day, 5 days/week) | NR M; 100 F | 100 M; 200 F | ND M; 17.9 F | 17.9 M; 35.7 F | Renal: Renal tubular degeneration | NTP 1987
Sprague-Dawley rat | 14 weeks (6 hours/day, 5 days/week) | 100 | 200 | 17.8 | 35.7 | Neurological: Decreased hindlimb grip strength | EPA 2005b
B6C3F1 mouse | Up to 14 weeks (6 hours/day, 5 days/week) | 100 | 200 | 17.9 | 35.7 | Respiratory:; Rhinitis | NTP 1987
B6C3F1 mouse | 10–11 weeks (6 hours/day, 5 days/week) | 100 | 250 | 17.9 | 44.6 | Hematological: Decreases in hemoglobin, erythrocyte count, packed cell volume, and/or mean corpuscular hemoglobin | Snellings et al. 1984a

a Duration-adjusted from intermittent exposure to a continuous exposure scenario.

b Duration-adjusted to continuous exposure using the time-weighted average for the exposure frequency (5.85 days/week, 6 hours/day).

ADJ = adjusted; F = female(s); LOAEL = lowest observed adverse effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; NR = not reported; PND = postnatal day; SLOAEL = serious LOAEL

Selection of the Principal Study: Among available intermediate-duration inhalation studies in laboratory animals, EPA (1994) identified the lowest NOAEL and LOAEL of 10 and 33 ppm, respectively. Therefore, EPA (1994) was selected as the principal study for derivation of the intermediate-duration inhalation MRL.

Summary of the Principal Study:

EPA. 1994. Data evaluation report: Ethylene oxide (EtO): Range-finding/developmental studies in rats (MRID #427977-01 and -02). D192811. Two generation reproduction study in rats (MRID #427881-01). D192453 (Previous 189547). Washington, DC: U.S. Environmental Protection Agency.

Groups CD rats (28/sex/group) were exposed by inhalation (whole body) to 0, 10, 33, or 100 ppm of ethylene oxide for 10 weeks premating (6 hours/day, 5 days/week), and during mating (2 weeks), gestation days 0–21, and lactation days 5–28 (6 hours/day, 7 days/week). The time-weighted exposure frequency for the study is 5.85 days/week for 6 hours/day. Parental animals were evaluated mortality, clinical signs, body weight, food consumption, organ weights (liver and lung), gross pathology, and histopathology, including reproductive organs. Uteri were examined to determine the total number of implantation sites. Litters were examined for numbers of live and stillborn pups, number of live and dead pups, sex, external anomalies, and pup body weight.

In F0 and F1 parents, no mortality or clinical signs were observed. Significant decreases in body weight gain were observed in F0 males in the 100 ppm group during the first 3 weeks of the pre-mating period (13–23%) and in F1 males in the 100 ppm group during the first (13%) and fifth (24%) weeks in the pre-mating period. A decrease in body weight was also reported in F1 males (7–11%) in the 33 ppm group “throughout study,” but data were not provided. No consistent treatment-related alterations in body weight gain were observed in the F0 or F1 females during the pre-mating period. Significant decreases in body weight gain were observed in F0 and F1 females in the 100 ppm group during gestation; the decreases in body weight in the F1 group were considered to be due to the reduced litter size in this group. Decreases in food consumption were observed in F0 and F1 lactating females. No treatment-related effects were observed for organ weights, or on gross pathological or histopathological examinations in males or females.

Reproductive and developmental effects were observed in F0 parents and F1 offspring at 33 and 100 ppm and in F1 parents and F2 offspring at 100 ppm. In F0 parents, post-implantation loss was increased to 14 and 41% in the 33 and 100 ppm groups respectively, compared to 7% in controls. The mean number of live births per litter was decreased by 36% in the 100 ppm group, compared to control. In F1 offspring, pup body weight on PND 21 was decreased by 7 and 13% in males in the 33 and 100 ppm groups, respectively. In female pups, body weight on PND 21 was decreased by 13% in the 100 ppm group. In F1 parents, post-implantation loss was increased to 42% in the 100 ppm group, compared to 11% in controls. The mean number of live births per litter were also decreased by 45% in the 100 ppm group, compared to control. In the 100 ppm group, alterations in F2 pup body weight were observed on PNDs 1 and 21. On PND 1, male and female body weights were increased by 10 and 9%, respectively, compared to controls; this was attributed to reduced litter size. In contrast, on PND 21, male and female body weights were decreased by 11%.

Selection of the Point of Departure for the MRL: Among intermediate-duration inhalation studies in laboratory animals, the 2-generation reproduction study in rats summarized by EPA (1994) identified the lowest LOAEL of 33 ppm for decreased F1 pup body weight in males on PND 21; data are presented in Table A-8. As noted in discussions above, post-implantation loss exposed to 33 and 100 ppm was also observed in this study. However, in a companion gestation-only exposure study (conducted by the same researchers using the same strain of rats with daily exposures on gestation days 6–15), post-implantation loss was not observed at exposure levels up to 250 ppm (EPA 1994). Additionally, the reproductive NOAEL and LOAEL values in a 1-generation study in F-344 rats were 33 and 100 ppm, respectively, based on a significant decrease in the ratio of the number of fetuses born per number of implantation sites (Snellings et al. 1982b). Due to observed discrepancies regarding the LOAEL for post-implantation loss, this endpoint was not selected as a co-critical effect for the intermediate-duration inhalation MRL. Data for pup body weight was not amenable to BMD analysis because measures of variance (e.g., standard deviation or standard error) for pup body weights were not reported. Therefore, the NOAEL of 10 ppm was selected as the POD.

Table A-8 Male Pup Body Weight in F1 Offspring of CD Rats Exposed to Ethylene Oxide in a 2-Generation Reproduction Study

Effect | Ethylene oxide exposure level (ppm)
Effect | 0 | 10 | 33 | 100
Body weight PND 21 (g) | 40.8 | 41.7^a^ (↑ 2.2%) | 38.0^b^ (↓6.9%) | 35.3^c^ (↓13.5%)

↑ = increase; ↓ = decrease; PND = postnatal day

a Values are means (% change from control)

b Significantly different from control (p<0.05)

c Significantly different from control (p<0.01)

Source: EPA 1994

Calculations

Intermittent Exposure: The NOAEL of 10 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

NOAEL_ADJ_ = NOAEL of 10 ppm × ( 6 hours / 24 hours ) × ( 5.85 days / 7 days ) = 2.1 ppm .

Human Equivalent Concentration: A PBPK modeling approach was initially considered to calculate a human equivalent to the rat NOAEL_ADJ_. Available PBPK models for ethylene oxide are described in Section 3.1.5. However, a PBPK modeling approach was rejected due to a lack of experimental data regarding the proper dose metric (proximate toxicant) for ethylene oxide-induced developmental effects. Therefore, a human equivalent concentration was calculated by multiplying the duration adjusted BMDL by the RGDR. The RGDR for extrarespiratory tract effects is the ratio of animal to human blood:gas partition coefficients.

NOAEL_HEC_ = NOAEL_ADJ_ × RGDR_ER_ NOAEL_HEC_ = NOAEL_ADJ_ × ( [ H_b/g_ ]_A_ / [ H_b/g_ ]_H_ )

[H_b/g_]_A_ = andecreaseimal blood/air partition coefficient = 64.1 for rats (Krishnan et al. 1992)

[H_b/g_]_H_ = human blood/air partition coefficient = 61 for humans (Csanady et al. 2000)

A default value of 1 for the ratio of blood/air partition coefficients for rats and humans was used because the rat blood/air partition coefficient was greater than the value for humans.

NOAEL_HEC_ = 2.1 ppm × 1 = 2.1 ppm

Uncertainty Factor and Modifying Factor: The NOAEL_HEC_ of 2.1 ppm was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans using dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HEC_ ÷ UF MRL = 2.1 ppm ÷ ( 3 × 10 ) = 0.07 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Gestational exposure studies in rats provide supporting evidence for developmental effects, specifically decreased pup body weight in dams exposed to inhaled ethylene oxide (Neeper-Bradley and Kubena 1993; NIOSH 1982; Saillenfait et al. 1996; Snellings et al. 1982a). LOAELs in these studies range from 100 ppm (Snellings et al. 1982a) to 800 ppm (Saillenfait et al. 1996).

The pre-public version of the ethylene oxide profile developed a provisional intermediate-duration inhalation MRL based on neurological effects. However, newly available data indicate that developmental effects are more sensitive than neurological effects. Therefore, the final intermediate-duration MRL for ethylene oxide was revised based on these developmental effects. The provisional neurological MRL in the pre-public version applied a modifying factor to address the insufficient assessment of functional neurological endpoints. However, since the endpoints in the developmental study were assessed thoroughly, ATSDR determined that no additional modifying factor was needed.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene Oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: Available chronic-duration inhalation data were not considered adequate for derivation of a chronic-duration inhalation MRL for ethylene oxide.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Case studies of neurological effects in workers exposed to ethylene oxide have been reported. These studies are insufficient to establish a causal relationship between exposure to ethylene oxide and neurological effects in humans. Neuropathy, impaired hand-eye coordination, cognitive dysfunction, memory loss, headache, and hand numbness were reported after occupational exposure to ethylene oxide (Brashear et al. 1996; Crystal et al. 1988; Dretchen et al. 1992; Estrin et al. 1987; Finelli et al. 1983; Kuzuhara et al. 1983; Salinas et al. 1981; Schröder et al. 1985; Zampollo et al. 1984). Sural nerve biopsies performed on two occupational groups revealed axonal degeneration and regeneration (Kuzuhara et al. 1983; Schröder et al. 1985).

The effects of chronic-duration inhalation exposure studies have been evaluated in monkeys (Lynch et al. 1984a), rats (Lynch et al. 1984a, 1984b; Snellings et al. 1984b), and mice (NTP 1987). Studies in monkeys and mice were not considered as potential principal studies. In cynomolgus monkeys intermittently exposed to ethylene oxide vapor for 2 years, decreased sperm count (28% less than controls) and motility (32% less than controls) were noted at the lowest exposure level tested (50 ppm) (Lynch et al. 1984a). However, evaluation of sperm parameters at cessation of exposures at 24 months included only two monkeys per group. Therefore, data are not adequate for derivation of the chronic-duration MRL. The NTP (1987) study in mice did not identify any noncancer effects at the highest exposure level tested (100 ppm); therefore, data from this study cannot be considered as the basis of the MRL.

The rat studies (Lynch et al. 1984b; Snellings et al. 1984b) were considered as principal studies for derivation of the chronic-duration inhalation MRL; however, ATSDR determined that they are inadequate to support derivation of an MRL. Exposure concentrations in these studies ranged from 10 to 100 ppm. Observed effects included decreased body weight (Lynch et al. 1984b; Snellings et al. 1984b) and alterations in the hematological, musculoskeletal, and endocrine systems (Lynch et al. 1984b). The NOAEL and LOAEL values for these effects are summarized in Table A-9. Lynch et al. (1984b) identified the lowest LOAEL of 50 ppm based on splenic extramedullary hematopoiesis and histopathological changes to the adrenal gland (multifocal vacuolization and hyperplasia). NOAEL values for these effects were not identified. However, ATSDR deemed the study inappropriate for MRL derivation because the rat colony experienced a Mycoplasma pulmonis infection during the study period. This infection was treated with antibiotics but did not appear to resolve and resulted in decreased survival. The potential contribution of the infection and stress associated with infection to adverse health effects is unknown, particularly regarding adrenal gland findings. Adrenal findings are further confounded by evidence that administration of antibiotics may induce adrenal hyperplasia in rats (Dickson et al. 1954; Dietz et al. 1991). Therefore, effects reported by Lynch et al. (1984b) at ≥50 ppm are of uncertain toxicological relevance due to concurrent infection. The other available rat study (Snellings et al. 1984b) identified a higher LOAEL of 100 ppm based on decreased body weight. However, potential non-neoplastic changes in the spleen may have been masked at 33 ppm due to increased incidence of mononuclear cell leukemia that was associated with marked splenomegaly in these rats. Therefore, an MRL based on body weight effects observed at 100 ppm may not be protective of potential nonneoplastic effects at lower exposure levels.

Table A-9 Summary of Selected NOAELs and LOAELs from Chronic-Duration Studies in Animals Exposed to Ethylene Oxide by Inhalation

Species | Exposure scenario | NOAEL (ppm) | LOAEL (ppm) | NOAEL_ADJ_^a^ (ppm) | LOAEL_ADJ_^a^ (ppm) | Effect | Reference
Body weight effects
Fischer 344 rat | 104 weeks; 5 days/week; 7 hours/day | 50 | 100 | 10.4 | 20.8 | 13% depressed body weight gain | Lynch et al. 1984b
Fischer 344 rat | 2 years; 5 days/week; 6 hours/day | 33 | 100 | 5.9 | 17.9 | Depressed body weight gain in males (up to 12%) and females (12–18%) | Snellings et al. 1984b
Hematological effects
Fischer 344 rat | 104 weeks; 5 days/week; 7 hours/day | ND | 50 | ND | 10.4 | Splenic extramedullary hematopoiesis | Lynch et al. 1984b
Musculoskeletal effects
Fischer 344 rat | 104 weeks; 5 days/week; 7 hours/day | 50 | 100 | 10.4 | 20.8 | Multifocal myopathy | Lynch et al. 1984b
Endocrine effects
Fischer 344 rat | 104 weeks; 5 days/week; 7 hours/days | ND | 50 | ND | 10.4 | Multifocal cortical vacuolation and hyperplasia in adrenal gland | Lynch et al. 1984b

a Duration-adjusted from intermittent exposure to a continuous exposure scenario.

ADJ = adjusted; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: Available acute-duration oral data were not considered adequate for derivation of an acute-duration oral MRL for ethylene oxide.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Available animal data are restricted to a single study in which 100% mortality occurred in rats treated with ethylene oxide by single gavage dose at 200 mg/kg; treatment at 100 mg/kg did not affect body weight (Hollingsworth et al. 1956).

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The intermediate-duration oral data were not considered adequate for derivation of an intermediate-duration oral MRL for ethylene oxide.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Available animal data are restricted to a single study in which gavage dosing of rats at 100 mg/kg/day for 15 or 22 treatments in 15 or 30 days resulted in weight loss, gastric irritation, and slight liver damage (not otherwise described); the NOAEL was 30 mg/kg/day (Hollingsworth et al. 1956). The lack of quantitative data precludes derivation of an intermediate-duration oral MRL for ethylene oxide.

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene oxide
CAS Numbers: | 75-21-8
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The chronic-duration oral data were not considered adequate for derivation of a chronic-duration oral MRL for ethylene oxide.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Available animal data are restricted to a single study in which gavage dosing at 30 mg/kg/day, 2 times/week for up to 150 weeks resulted in decreased survival; forestomach squamous cell carcinoma (at the application site for oral gavage) was reported at 7.5 mg/kg/day (Dunkelberg 1982).

Agency Contacts (Chemical Managers): Jennifer Przybyla