# 7 ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring ethylene glycol, its metabolites, and other biomarkers of exposure and effect to ethylene glycol. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

Table 7-1 is a summary of some of the most commonly used methods reported in the literature for detecting ethylene glycol in biological samples. The primary method for measuring ethylene glycol in biological samples is derivatization followed by gas chromatography (GC) using either a flame ionization detector (FID) or mass spectrometry (MS) for quantification. GC is the preferred analytical method because of the ease of sample preparation and the accuracy of the quantification of sample concentrations. Alkali flame ionization detectors have also been used for ethylene glycol analysis and give a response ratio of 3:1 compared with FID (Bogusz et al. 1986).

Sample preparation for GC is important and proceeds through several steps: acidification, esterification, and extraction into an organic solvent. The use of internal standards is necessary for quantification.

Detection of ethylene glycol in biological samples using GC with either FID or MS is very sensitive, with detection limits ranging from sub to low ppm. The coefficient of variation (CV) varies with the concentration of glycol used but typically ranges from 0.4 to 27% and is usually <10%. In GC procedures, the glycols and their acid metabolites are derivatized to form esters in order to facilitate quantitative elution from the chromatographic columns (see Table 7-1). Yao and Porter (1996) and Porter et al. (1999) have developed a procedure for the simultaneous determination of ethylene glycol and glycolic acid in human serum. The entire procedure can be completed in <2 hours. Simple and rapid methods are also available for the quantitation of the glycols in urine, serum, or deproteinated whole blood. These methods use direct sample injection without prior solvent extraction and derivatization (Aarstad et al. 1993; Edinboro et al. 1993; Jonsson et al. 1989). However, such methods, particularly those that use packed columns may misidentify propionic acid (found in patients with methylmalonic acidemia) as ethylene glycol (Shoemaker et al. 1992).

Table 7-1 Analytical Methods for Determining Ethylene Glycol inBiological Materials

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Human plasma | Deproteinization with acetic acid; vortex; centrifugation; supernatant spiked with internal standard; reaction with butyl-boronic acid; neutralize with NH_4_OH, extraction with dichloromethane; concentration. | HRGC/MS | 5 ppm | 94-106 | Giachetti et al. 1989
Human serum | Internal standard (in acetonitrile) added to sample; centrifugation to remove protein precipitate; esterification with butylboronic acid and 2,2-dimethoxypropane; neutralization with NH_4_OH in acetonitrile. | HRGC/FID | NR | 95 | Smith 1984
Human serum (ethylene glycol and glycolic acid) | Addition of internal standard (in acetonitrile) followed by centrifugation. Supernate is treated with 2,2-dimethoxy-propane/dimethylformamide. Volume is then reduced, but not to dryness. | GC/MS | 10 ppm | 91.1% (ethylene glycol); 77.6% (glycolicacid) | Porter et al. 1999
Human serum | Deprotonization of samples via ultrafiltration followed by addition of internal standard to the filtrate and injection into the GC. | CCGC | 10 ppm | NR | Williams et al. 2000
Human serum and urine | Internal standard added; centrifugation; derivatization with phenylboronate in methanol. | HRGC/FID | 1.0 ppm | 89–98 | Houze et al. 1993
Human blood/tissue | Anhydrous Na_2_SO_4_ ground with sample; derivatization with n-butylboronic acid in acetone containing internal standard; centrifugation or filtration. | GC/FID/AFID | NR | 70 | Bogusz et al. 1986
Human serum (glycolic acid) | Colorimetric: precipitation of protein with trichloroacetic acid followed by centrifugation, addition of chromotropic acid, heating, and dilution; gas chromatographic: addition of internal standard and acetone followed by centrifugation, addition of NaOH, evaporation to dryness, and formation of methyl ester. | Absorbance at 580 nm or GC/FID as appropriate | 1.0 mmol/L (60 ppm, w/v) for both methods; 3–6% RSD | NR | Fraser and MacNeil 1993
Humans serum (glycolic acid) | Extraction from salted, acidified serum using methyl ethyl ketone followed by removal of organic phase and evaporation to dryness and derivatization with PNBDI. | HPLC/UV | 0.05 mmol/L (3 ppm, w/v); 1% RSD | NR | Hewlett et al. 1986
Urine | Acidification; extraction with CHCl_3_; concentration; TLC. | TLC | NR | NR | Riley et al. 1982
Urine (sodium fluorescein) | Untreated samples read in borosilicate tubes. | Fluorescence (Wood’s lamps) | NR | NR | Winter et al. 1990
Dog urine (glycolic acid) | Dilution; NaCl addition and acidification; extraction in MEK; evaporation; dissolution of residue in ethylacetate; derivatization with PNBDl. | HPLC/UV | 1–2 ng | 96 | Hewlett et al. 1983
Human plasma, urine (oxalate) | Heparinized blood deproteinated by addition of acetonitrile and phosphate buffer (pH=7), centrifugation, removal of solvent and evaporation to dryness; derivatization as for urine; urine acidified and derivatized using 1,2-diaminobenzene, adjustment of pH to 5-6, centrifugation. | HPLC/UV | Plasma: 0.15 mg/L (ppm, w/v); 7.5% RSD; urine: 0.5 mg/L (ppm, w/v); 5% RSD. | 85 | Brega et al. 1992
Kidney tissue dog (hippurate) | Tissue ground with acidic methanol; filtration; concentration; spot on 254 nm TLC plate. | TLC | NR | NR | Riley et al. 1982
Human tissue | Samples extraction in HPLC grade water for 24 hours; filtration of supernatant. | HPLC/RI | 5 ppm | 98 at 1 mg/mL (1,000 ppm) | Wu and Malinin 1987

AFID = alkali flame ionization detector; ATP = adenosine triphosphate; CHCl_3_ = chloroform; CH_3_OH = methanol; CCGC = Capillary column gas chromatography; ECD = electron capture detector; EG = ethylene glycol; FID = flame ionization detector; GC = gas chromatography; HCl = hydrochloric acid; HClO_4_ = chloroform; HPLC = high-performance liquid chromatography; HRGC = high resolution gas chromatography; KOH = potassium hydroxide; MEK = methylethyl ketone; MgSO_4_ = magnesium sulfate; MS = mass spectrometry; NaCl = sodium chloride; NAD = nicotinamide adenine dinucleotide; Na_2_SO_4_ = sodium sulfate; NH_4_OH = ammonium hydroxide; NR = not reported; PG = propylene glycol; PNBDl = O-p-nitrobenzyl-N.N′-diisopropylisourea; RSD = relative standard deviation; RI = refractive index detector; TLC = thin-layer chromatography; UV = ultraviolet detector; w/v = weight:volume

High performance liquid chromatography (HPLC) has also been used to identify ethylene glycol and its metabolites such as glycolate (Hewlett et al. 1983, 1986), hippurate (Riley et al. 1982), and oxalate (Brega et al. 1992) in biological samples, particularly blood and urine. Positive results may be confirmed with GC/MS. This makes GC/MS the preferred method since the HPLC step can be omitted. However, HPLC methods to measure plasma levels of glycolate have been used to aid in diagnosis and treatment of ethylene glycol poisoning (Hewlett et al. 1986; Jacobsen et al. 1988). Gas chromatographic and colorimetric methods for quantification of glycolate have been presented (Fraser and MacNeil 1993).

Microscopy can be used to identify metabolic products of ethylene glycol. Scanning electron microscopy (SEM) at 20 kilovolts will detect crystals of calcite, calcium oxalate monohydrate, and calcium oxalate dihydrate in kidney tissue (Siew et al. 1975b). Phase-contrast polarization and light microscopy X-ray powder diffraction may be used to identify hippuric acid crystals in urine (Foit et al. 1985).

The use of ethylene oxide to sterilize tissue for transplantation may result in the formation of ethylene glycol when ethylene oxide is in prolonged contact with tissue. To quantify the formation of ethylene glycol in tissue, an HPLC method using a differential refractive index detector has been developed. The HPLC system can be used to detect ppm levels of ethylene glycol with a sensitivity of 2×10^−6^ refractive index unit full scale. This procedure has three advantages: (1) requires only 4 minutes for analysis, (2) simple sample preparation, and (3) good reproducibility (Wu and Malinin 1987).

Techniques using GC and various detection systems to detect and quantify ethylene glycol in human blood have been developed for use in hospital laboratories to assist in the diagnosis of ethylene glycol poisoning (caused by drinking antifreeze containing ethylene glycol). These techniques are quite rapid, usually <30 minutes, and do not require elaborate sample preparation. The specific techniques used for each analytical method are listed in the table if that information was provided by the author(s).

An alternative method, developed in a hospital, for detecting ethylene glycol in blood is the use of the DuPont Automated Clinical Analyzer triglyceride assay pack. This enzymatic method, while relatively simple, cannot be used when the triglyceride concentration of the serum exceeds 12 g/L and requires that positive results for ethylene glycol be confirmed using another method (Ochs et al. 1988; Ryder et al. 1986). The enzymatic method has been modified to eliminate some of the interference problems present in the earlier methods (Blandford and Desjardins 1994).

Thin-layer chromatography (TLC) with a chloroform solvent has been used to detect ethylene glycol and its metabolites in urine or renal tissue (Riley et al. 1982). Metabolites of ethylene glycol in the blood may be detected by analytical isotachophoresis using a system equipped with both a conductivity detector and an ultraviolet detector. Blood and serum samples should not have been previously treated with oxalate, citrate, or ethylene diamine tetracetic acid. This technique may be of value when ethylene glycol poisoning is suspected but sufficient time has elapsed for metabolism of the compound to have occurred (Ovrebo et al. 1987). A simple and rapid colorimetric method that uses chromatropic acid has been proposed for the quantitation of glycolic acid, the major toxic metabolite of ethylene glycol (Fraser and MacNeil 1993).

No information was located on detecting ethylene glycol in feces, adipose tissue, or human milk.

## 7.2 ENVIRONMENTAL SAMPLES

As with biological samples, GC is the major technique used to determine ethylene glycol concentrations in environmental samples whether in air, water, food, drugs, or other substances. Capillary gas chromatography with FID or ECD, possibly followed by MS, generally gives good quantitative results down to the ppm range with recovery usually >80%. The determination of ethylene glycol in air requires adsorption onto a surface and subsequent extraction. Water samples may be analyzed without preparation (EPA 1995a, 1995b). Detection of ethylene glycol in foods and drugs may be accomplished by chromatography of the sample; for substances with a high fat content, extraction with hexane may be used to remove the fat. Table 7-2 is a summary of some of the most commonly used methods reported in the literature for detecting ethylene glycol in environmental samples. The specific techniques used for each analytical method are listed in the table if that information was provided by the author(s).

Air sampling for ethylene glycol is performed by adsorption onto a resin column such as Amberlite XAD-2. Although activated charcoal filters have some utility, recovery is greater with the Amberlite, and it is the preferred adsorption medium. Ethylene glycol is then solvent-extracted with recovery of 98%. If activated charcoal is used for adsorption, 5% methanol in dichloromethane is the best solvent with maximum recovery of 84% (Andersson et al. 1982, 1984). An alternative method for sampling ethylene glycol involves passage of air through a glass fiber filter with a silica gel tube. Ethylene glycol is then extracted in a 2-propanol:water solvent mixture and injected into the gas chromatograph (Tucker and Deye 1981). A similar version of this method is the NIOSH-approved method for the determination of ethylene glycol in occupational air (see Table 7-2).

Table 7-2 Analytical Methods for Determining Ethylene Glycol inEnvironmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Air | Sample collection on glass fiber filters and silica gel; extraction with methanol; ultrasonic bath (Method 5523). | GC/FID | 0.05 ppm | 93.4–101 | NIOSH 1996
Air | Sample adsorbed on Amberlite^®^ XAD-2 with personal sampling pump; extraction with diethyl ether. | GC/FID | NR | 75–98 | Andersson et al. 1982
Water | Direct injection (Method 8015C). | GC/FID | NR | NR | EPA 2000
Water | Direct injection (Method 8430). | GC/FTIR | NR | NR | EPA 1996
Plastics | Sample extraction from plastic with carbon disulfide. | GC/FID | 16.5 ng | 58–61 | Muzeni 1985
Plastics | Sample extraction with solvent of ethylacetate-water-methanol. | GC/FID | 2 ppm | NR | De Rudder et al. 1986
Ground tobacco | Extraction with anhydrous methanol. | GC/FID | NR | NR | AOAC 1990b
Aqueous solution | Sample concentration, then dilution with water; concentration with helium gas; redilution. | GC/FID | 50 ppb | 97–103 | Kashtock and Breder 1980
Beer | Addition of ammonium sulfate and extract with ethyl acetate. | HRGC/FID | 0.73 ppm | 88 | Williamson and Iverson 1993
Food | Addition of hot water to sample to obtain slurry; extraction with hexane; precipitation of sugars with calcium hydroxide; concentration; derivatization with BSTFA. | HRGC/FID;GC/MS | 10 ppm | 78–107 | Castle et al. 1988b
Anchovies | Extraction with methanol and concentration. | HRGC/MS/MS (PICI) | 12.5 ppb | NR | Matusik et al. 1993

BSTFA = bis(trimethylsilyl)trifluoroacetamide; FID = flame ionization; GC = gas chromatography; HRGC = high resolution gas chromatography; MS = mass spectrometry; MS/MS = tandem mass spectrometry; PICI = positive ion chemical ionization

A portable, automated, photoionization gas chromatograph has been used to detect ethylene glycol in air samples in industrial facilities at levels as low as 0.05 ppm (Adams and Collins 1988).

Ethylene glycol may be detected by a colorimetric reaction with 3-methyl-2-benzothiazolinone hydrazone hydrochloride after oxidation of the glycols to the corresponding aldehydes with acidified permanganate. The solution is read at 630 nm in a spectrophotometer. This method may be used for ethylene glycol in water (Evans and Dennis 1973) or to detect ethylene oxide in air (Kring et al. 1984); however, this method is not quantitative and is relatively insensitive compared with GC/MS.

The migration of ethylene glycol from plastics into solution can be studied with GC. Sample preparation methods include extraction in hydrochloric acid (Ball 1984), distilled water (Spitz and Weinberger 1971), carbon disulfide (Muzeni 1985), dimethylformamide (Danielson et al. 1990), and a mixture of ethyl acetate, water, and methanol (De Rudder et al. 1986). Other methods for detecting ethylene glycol in industrial products include HPLC (Aboul-Enein and Islam 1989) and a periodate flow-through ionselective electrode (Diamandis et al. 1980).

The presence of ethylene glycol in foods packaged with plastic films containing the compounds has been studied, as have ethylene glycol levels in drugs sterilized with ethylene oxide. Sample preparation is important because procedures vary depending on the fat content of the food sample. Foods with low fat content can be extracted with ethyl acetate, derivatized to a trimethylsilyl ether, and then injected into the gas chromatograph. For foods with a high fat content, hexane is used as the defatting agent prior to derivatization. Quantifying ethylene glycol in wines requires no preparation of the samples prior to analysis (Kaiser and Rieder 1987; Klaus and Fischer 1987). Drugs in aqueous solutions may be analyzed directly, water insoluble drugs should be extracted in water, and ointments may be dissolved in hexane and then extracted with water. Recovery is between 80 and 114%, with detection limits in the low-ppm range (Hartman and Bowman 1977; Manius 1979). Although the use of TLC (Ballarin 1980) has been recommended, it has been superseded by GC.

No information was located on techniques for detecting and analyzing ethylene glycol in soil.

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of ethylene glycol is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of ethylene glycol.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 7.3.1 Identification of Data Needs

#### Methods for Determining Biomarkers of Exposure and Effect

Exposure. Methods are available for the determination of ethylene glycol in blood, tissue, and urine (Bogusz et al. 1986; Giachetti et al. 1989; Houzé et al. 1993; Riley et al. 1982; Smith 1984; Wu and Malinin 1987) with sensitivities in the low and sub-ppm range. Methods are also available for metabolites of ethylene glycol (glycolic acid, oxalic acid) in blood and urine (Brega et al. 1992; Fraser and MacNeil 1993; Hewlett et al. 1986) with sensitivities as low as 3 ppm for glycolic acid and of 0.15 ppm for oxalic acid. Glycolic acid was identified in Chapter 3 as a sensitive biomarker of exposure to ethylene glycol. These methods seem to be adequate for the measurement of ethylene glycol and its metabolites in the human population.

Effect. Serum concentrations of blood urea nitrogen (BUN) or creatinine can serve as indicators of renal toxicity induced by exposure to ethylene glycol, but these are not specific for ethylene glycol intoxication (Grauer et al. 1987).

Methods for Determining Parent Compounds and Degradation Products in Environmental Media. Methods for the determination of ethylene glycol have been reported for air (Andersson et al. 1982; NIOSH 1996), water or aqueous solutions (EPA 1996, 2000; Kashtock and Breder 1980), and foods (Castle et al. 1988b; Matusik et al. 1993; Williamson and Iverson 1993). Methods have also been developed for the determination of glycols that leach from plastics (De Rudder et al. 1986; Muzeni 1985) and can end up in foods stored in containers made from the plastics.

The MRL for inhalation exposure to ethylene glycol is 0.5 ppm and thus requires a method level of detection (LOD) of 0.5 ppm. This value is below the LODs of the methods reported. Although it should be possible to increase the sampling volumes and increase the sensitivities of the methods, this would need to be shown to be free of problems. Oral MRLs have been established to be 2 mg/kg/day for acute exposure and 0.2 mg/kg/day for chronic exposure. Assuming a 70-kg individual and oral intakes of either 2 L/day of water or 2 kg/day of food, analytical methods would need sensitivities <70 ppm in water or food. The methods reported for aqueous solutions (LOD=50 ppb, Kashtock and Breder 1980), beer (LOD=0.73 ppm, Williamson and Iverson 1993), and foods (LOD=10 ppm, Castle et al. 1988b; LOD=12.5 ppb, Matusik et al. 1993) should be adequate to measure acute exposure. However, chronic exposure requires method LODs of approximately 7 ppm and only the methods of Kashtock and Breder (1980) for aqueous solutions, Williamson and Iverson (1993) for beer, and Matuslik et al. (1993) for anchovies can meet this requirement. The applicability of these methods to other beverages and foods has not been demonstrated. Thus, additional methods should be developed and validated for ethylene glycol in other beverages and foods at concentrations relevant to the chronic oral MRL.

### 7.3.2 Ongoing Studies

Ongoing studies related to the potential for human exposure to ethylene glycol were not located.