# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of ethylene glycol is located in Table 4-1. This information includes synonyms, chemical formula and structure, and identification numbers.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of ethylene glycol is located in Table 4-2.

Table 4-1 Chemical Identity of Ethylene Glycol^a^

Characteristic | Information
Chemical name | Ethylene glycol
Synonyms and trade names | 1,2-Dihydroxyethane; 1,2-ethandiol; 1,2-ethane-diol; 2-hydroxyethanol; ethylene alcohol; ethylene dihydrate; glycol; monoethylene glycol; MEG; Lutrol-9; Dowtherm Sr 1; Fridex; Norkool; Ramp; Tescol; Ucar 17
Chemical formula | C_2_H_6_O_2_
Chemical structure | [image]
Identification numbers:
CAS registry | 107-21-1
NIOSH RTECS | KW2975000^b^
EPA hazardous waste | No data
DOT/UN/NA/IMDG shipping | No data
HSDB | 5012
NCI | C00920

a All information obtained from HSDB 2009 except where noted.

b NIOSH 2005

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Ethylene Glycol^a^

Property | Ethylene glycol
Molecular weight | 62.07
Color | Clear, colorless^b^
Physical state | Liquid^b^
Melting point | −12.69 °C^c^
Boiling point | 197.3 °C^c^
Density:
at 20 °C (g/cm^3^) | 1.1135^d^
Vapor density | 2.14 (air=1)
Odor | Odorless
Odor threshold | No data
Solubility:
Water at 20 °C | Miscible with water
Organic solvent(s) | Soluble in lower aliphatic alcohols, glycerol, acetic acid, acetone; slightly soluble in ether; practically insoluble in benzene, chlorinated hydrocarbons, petroleum ether, oils.
Partition coefficients:
Log K_ow_ | −1.36^e^
K_oc_ | 1 (estimated)
Vapor pressure at 25 °C | 0.089 mm Hg (extrapolated)^f^
Henry’s law constant at 25 °C | 6×10^−8^ atm-m^3^/mole^g^
Autoignition temperature | 398 °C
Flashpoint | 127 °C^h^
Explosive limits | 3.20–53%^i^
Conversion factors | 1 ppm = 2.58 mg/m^3^; 1 mg/m^3^ = 0.39 ppm

a All information obtained from HSDB 2009, except where noted.

b Lewis 2001

c Lide 2005

d O’Neil et al. 2001

e Hansch et al. 1995

f AIChE 1995

g Hine and Mookerjee 1975

h Forkner et al. 2004

i Rebsdat and Mayer 2005