# PEER REVIEW

A peer review panel was assembled for ethylbenzene. The panel consisted of the following members:

Draft for Public Comment:

1 John DeSesso, Ph.D., Senior Fellow, Noblis, Falls Church, VA;
2 James McDougal, Ph.D., Professor and Director of Toxicology Research, Boonshoft School of Medicine, Wright State University, Department of Pharmacology and Toxicology, Dayton, OH;
3 Andrew Salmon, Ph.D., Senior Toxicologist and Chief, Air Toxicology and Risk Assessment Unit, Office of Environmental Health Hazard Assessment, California Environmental Protection Agency, Oakland, CA.

Revised Minimal Risk Levels:

4 John DeSesso, Ph.D., Senior Fellow, Noblis, Falls Church, VA;
5 Brent Finley, Ph.D., DABT, Principal Health Scientist and Vice President, ChemRisk, San Francisco, CA;
6 Andrew Salmon, Ph.D., Senior Toxicologist and Chief, Air Toxicology and Risk Assessment Unit, Office of Environmental Health Hazard Assessment, California Environmental Protection Agency, Oakland, CA.

These experts collectively have knowledge of ethylbenzene’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.