# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Ethylbenzene is an aromatic hydrocarbon that occurs naturally in petroleum and is a component of aviation and automotive fuels. It is used as a solvent and in the production of synthetic rubber and styrene. Information regarding the chemical identity of ethylbenzene is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Ethylbenzene is a colorless liquid with an aromatic odor. Information regarding the physical and chemical properties of ethylbenzene is located in Table 4-2. Ethylbenzene is a flammable and combustible liquid. Vapors are heavier than air and may travel to a source of ignition and flash back. Liquid ethylbenzene floats on water and may travel to a source of ignition and spread fire. Combustion may produce irritants and toxic gases (HSDB 2009; NFPA 1994). Ethylbenzene may accumulate static electricity and will react with oxidizing materials (HSDB 2009; NFPA 1994).

Table 4-1 Chemical Identity of Ethylbenzene

Characteristic | Information | Reference
Chemical name | Ethylbenzene | Budavari and O’Neil 1989
Synonym(s) | EB; ethyl benzene; benzene, ethyl-; ethylbenzol; phenylethane; etilbenzene; ethylbenzeen; aethylbenzo; etylobenzen | HSDB 2009
Registered trade name(s) | No data
Chemical formula | C_8_H_10_ | Cannella 2007
Chemical structure | [image] | Cannella 2007
Identification numbers:
CAS registry | 100-41-4 | Cannella 2007
NIOSH RTECS | NIOSH/DA0700000 | NIOSH 2009; RTECS 2009
EPA hazardous waste | F003 | HSDB 2009
OHM/TADS | 7216709 | HSDB 1995
DOT/UN/NA/IMDG shipping | UN 1175; IMDG 3.2 | HSDB 2009
HSDB | 84 | HSDB 2009
NCI | NCI-C56393 | HSDB 2009
STCC | 49 091 63 | HSDB 2009

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances; STCC = Standard Transport Commodity Code

Table 4-2 Physical and Chemical Properties of Ethylbenzene

Property | Information | Reference
Molecular weight | 106.17 | Lide 1994
Color | Colorless | Welch et al. 2005
Physical state | Liquid | Welch et al. 2005
Melting point | −94.975 °C | Cannella 2007
Boiling point | 136.19 °C | Cannella 2007
Density at 20 °C/4 °C | 0.8670 | Welch et al. 2005
at 25 °C/25 °C | 0.8671 | Cannella 2007
Odor | Sweet, gasoline-like | CHRIS 1985
Odor threshold:
Water | 0.029 mg/L | Amoore and Hautala 1983
| 0.140 mg/L | Rosen et al. 1963; Verschueren 1983
Air | 2.3 ppm | Amoore and Hautala 1983
| 2–2.6 mg/m^3^ | Verschueren 1983
Solubility:
Water at 0 °C | 197 mg/L | Polak and Lu 1973
at 15 °C | 140 mg/L | Verschueren 1983
at 20 °C | 152 mg/L | Verschueren 1983
at 25 °C | 160 mg/L | Amoore and Hautala 1983
at 25 °C | 177 mg/L | Polak and Lu 1973
at 25 °C | 208 mg/L | Bohon and Claussen 1951
Organic solvents | Miscible with usual organic solvents | Budavari and O’Neil 1989
| Soluble in alcohol and ether | Lide 1994
Partition coefficients:
Log K_ow_ | 4.34 | EPA 1982
| 3.13 | Yalkowsky and Valvani 1976
| 3.15 | Hansch et al. 1995
Log K_oc_ | 2.22 (calculated) | Chiou et al. 1983
| 2.38 (measured) | Hodson and Williams 1988
| 2.40 (calculated) | Vowles and Mantoura 1987
Vapor pressure
at 20 °C | 7 mm Hg | Verschueren 1983
at 25 °C | 1.27 kPa (9.53 mm Hg) | Mackay and Shiu 1981
at 25.9 °C | 10 mm Hg | Sax and Lewis 1989
at 30 °C | 12 mm Hg | Verschueren 1983
Henry’s law constant:
at 20 °C | 6.6×10^−3^ atm-m^3^/mol | EPA 1982
at 20 °C | 8.7×10^−3^ atm-m^3^/mol | Lyman et al. 1982
at 25 °C | 8.43×10^−3^ atm-m^3^/mol | Mackay et al. 1979
at 25 °C | 7.9×10^−3^ atm-m^3^/mol | Mackay and Shiu 1981
Autoignition temperature | 810 °F (432 °C) | Cannella 2007; NFPA 1994;
Flash point | 15 °C | Cannella 2007
Flammability limits | 0.8 (lower) vol%–6.7 (upper) vol% | NIOSH 2005
Conversion factors | 1 mg/m^3^=0.230 ppm | NIOSH 2005; Verschueren 1983
(25 °C, 1 atm) | 1 ppm=4.34 mg/m^3^