# 8 REFERENCES

*Cited in text

*Aaron CK, Howland MA. 1990. Organophosphates and other insecticides. In: Haddad LM, and Winchester JF, eds. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders, 1105–1119.
ACGIH. 1991. Documentation of the threshold limit values and biological exposure indices. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
ACGIH. 1997a. Documentation of the threshold limit values for the substances in workroom air. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1997b. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1997. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*ACGIH. 1999. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1999. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
Adhya TK, Sudhakar-Barik, Sethunathan N. 1981. Hydrolysis of selected oganophosphorus insecticides by two bacteria isolated from flooded soil. J Appl Bacteriol 50:167–172.7228819
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Adinolfi M. 1985. The Development of the Human Blood-CSF-Brain Barrier. Dev Med Child Neurol 27:532–537.4029526
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book, Volume III, second edition. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987-2008, 2041.
*Andersen ME, Krishman K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: H. Salem, ed. Current concepts and approaches on animal test alternatives. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andersen ME, MacNaughton MG, Clewell HJ, . 1987. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Arizona Department of Health Services. 1999. Ethion. Environment Health. http://www.hs.state.az.us/
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicologicol profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Bailey DE. 1988. 90-Day subchronic toxicity study of ethion technical in dogs (A86-1990). Unpublished revised final report dated June 21, 1988 by Hazelton Laboratories America, Inc., Vienna, Va for FMC Corp., Princeton, NJ. EPA MRID No. 40773301.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Bason CW, Colborn T. 1992. U.S. application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. In: Colborn T, Clement C, eds. Chemically-induced alterations in sexual and functional development: The wildlife/human connection. Advances in Modern Environmental Toxicology, Vol. XXI. Princeton, NJ: Princeton Scientific Publishing Co., Inc., 335–345.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Berry MR, Johnson LS, Jones JW, . 1997. Dietary characterizations in a study of human exposures in the lower Rio Grande Valley: I. Foods and beverages. Environment International 23(5):675–692.
*Bhunya SP, Jena GB. 1994. Evaluation of genotoxicity of a technical grade organophosphate insecticide, tafethion (ethion), in chicks. In Vivo 8:1087–1090.7772742
*Blair D, Dix KM, Hunt PF, . 1976. Dichlorvos — a 2-year inhalation carcinogenesis study in rats. Arch Toxicol 35(4):281–294.989297
*BNA. 1998. BNA’s Environmental Library on CD (ELCD). States and Territories. Folio Infobase. The Bureau of National Affairs, Inc. 123125^th^ Street, NW. Washington, DC 20037.
*Bowman BT, Sans WW. 1983. Determination of octanol-water partitioning coefficients (K_ow_) of 61 organophosphorus and carbamate insecticides and their relationship to respective water solubility (s) values. J Environ Sci Health B18(6):667–683.
*Braun HE, Frank R. 1980. Organochlorine and organophosphorus insecticides: Their use in eleven agricultural watersheds and their loss to stream waters in Southern Ontario, Canada, 1975-1977. Sci Total Environ 15:169–192.
*Brodeur J, DuBois KP. 1963. Comparison of acute toxicity of anticholinesterase insecticides to weanling and adult male rats. Proc Soc Expl Biol Med 114:509–511.
*Butler PA, Schutzmann RL. 1978. Fish, wildlife, and estuaries: Residues of pesticides and PCBs in estuarine fish, 1972-76--National Pesticide Monitoring Program. Pestic Monit J 12(2):51–59.101966
*Carey AE, Gowen JA, Tai H . 1978. Pesticide residue levels in soils and crops, 1971- National Soils Monitoring Program (III). Pesticide Monit J 12(3):117–136.
*Carey AE, Gowen JA, Tai H, . 1979. Pesticide residue levels in soils and crops from 37 states, 1972 - National Soils Monitoring Program (IV). Pestic Monit J 12:(4)209–229.461116
*Chapman RA, Cole CM. 1982. Observations on the influence of water and soil pH on the persistence of insecticides. J Environ Sci Health B17:487–504.
*Chapman RA, Harris CR, Svec HJ, . 1984. Persistence and mobility of granular insecticides in an organic soil following furrow application for onion maggot control. J Environ Sci Health B 19:(3)259–270.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Cohen DB. 1986. Ground water contamination by toxic substances: A California assessment. In: Garner WY . eds. Evaluation of pesticides in ground water (ACS Symposium Series). Am Chem Soc Symp Ser 315:499–529.
*Comstock EG, Bickel L, McCormick RA Jr. 1967. Acute ethion poisoning. Tex Med 63(6):71–75.
*Corneliussen PE. 1970. Residues in food and feed: Pesticide residues in total diet samples (v). Pestic Monit J 4(3):89–105.5489544
*Cowart RP, Bonner FL, Epps EA, Jr. 1971. Rate of hydrolysis of seven organophosphate pesticides. Bull Environ Contam Toxicol 6(3):231–234.4115900
*Davies JE, Freed VH, Enos HF, . 1982. Reduction of pesticide exposure with protective clothing for applicators and mixers. J Occup Med 24(6):464–468.7097378
DHHS. 1995. Report to Congress on workers’ home contamination study conducted under the workers’ family protection act (29 U.S.C. 671a). U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health, Cincinnati, OH.
*Dierberg FE, Pfeuffer RJ. 1983. Fate of ethion in canals draining a Florida citrus grove. J Agric Food Chem 31(4):704–709.
*Di Muccio A, Pelosi P, Camoni I, . 1996. Selective, solid-matrix dispersion extraction of organophosphate pesticide residues from milk. J Chromatog A 754(1–2):497–506.8997741
*Dreisbach RH, Robertson WO. 1987. Handbook of poisoning: prevention, diagnosis & treatment. Norwalk, CT: Appleton & Lange. 110–118.
*DuBois KP, Kinoshita FK. 1968. Influence of induction of hepatic microsomal enzymes by phenobarbital on toxicity of organic phosphate insecticides. Proc Soc Exp Biol Med 129:699–702.5725078
Duggan RE, Corneliussen PE. 1972. Dietary intake of pesticide chemicals in the United States (III), June 1968-1970. Pestic Monit J 5:331–341.4133965
*Ecobichon DJ. 1991. Toxic effects of pesticides. In: Amdur MO, Doull J, Klassen DC, eds. Casarett and DoullÆs Toxicology: The basic science of poisons, 4th ed. New York, NY: McGraw-Hill, Inc., 565–622.
*Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in River Water. Environ Sci Technol 5(6):541–544.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the great lakes ecosystem. Environ Sci Technol 15(1):30–38.
*Enloe P, Salamon C. 1985. Three-generation reproduction study in albino rats with ethion (FMC 1240) technical: Unpublished report dated July 30, 1985 by American Biogenics Corporation, Decatur IL for FMC Corp., Princeton, NJ. EPA MRID No. 00148989.
*EPA. 1981. Engineering handbook for hazardous waste incineration. U.S. Environmental Protection Agency, Office of Water and Waste Management. Washington DC SW-889, EPA 68-03-3025.
*EPA. 1986. Broad scan analysis of the FY82 national human adipose tissue survey specimens. (NHATS). Volume III - semi-volatile organic compounds. U.S. Environmental Protection Agency. Office of toxic substances. EPA 560/5-86-037. December 1986.
EPA. 1989a. Designation of hazardous substances. List of Hazardous Substance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1989b. Pesticide fact sheet no. 209: ethion. Govt Reports Announcements & Index (gra&i), 1989.
*EPA. 1989c. Pesticides in ground water data base: 1988 interim report. U.S. environmental protection agency, office of pesticide programs. Washington, DC. EPA-540/09-89-036.
*EPA. 1989d. Guidance for the reregistration of pesticide products containing ethion as the active ingredient. U.S. environmental protection agency. Washington, DC. Dated September 29, 1989.
*EPA. 1990. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1992. Methods for the determination of nonconventional pesticides in municipal and industrial wastewater, method 614.1. The determination of organophosphorus pesticides in municipal and industrial wastewater. EPA 821 RR-92-002. Office of Water, Washington, DC. 81–95.
EPA. 1993a. Effluent guidelines and standards. Pesticide chemicals. Organic pesticide chemicals manufacturing subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Subpart A; Tables 1, 2, and 3.
EPA. 1993b. Effluent guidelines and standards. Pesticide chemicals. Test methods for pesticide pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Subpart D; Table 7.
*EPA. 1994. Standards for pesticide containers and containment (proposed rule). U.S. Environmental Protection Agency. 59 FR 6712. February 11, 1994.
*EPA. 1995a. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notification. Designation of hazardous substances. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1995b. Title III. List of Lists. Consolidated list of chemicals subject to the emergency planning and community right-to-know act (EPCRA) and section 112(r) of the clean air act, as amended. EPA 740-R-95-001. April 1995.
EPA. 1995c. Water programs. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1995d. Water programs. EPA administered permit programs: The national pollutant discharge elimination system. Permit application testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D; Table V.
*EPA. 1995e. Toxic chemical release inventory reporting form R and instruction. U.S. environmental protection agency, office of pollution prevention and toxics. Washington, DC. EPA 745-K-95-051.
*EPA. 1995f. Toxic release inventory reporting modifications beginning with 1995 reporting year. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. Washington, DC. EPA 7 45-R-95-009.
*EPA. 1995g. Guidance for assessing chemical contaminant data for use in fish advisories. Volume 1: Fish Sampling and Analysis. 2nd ed. Office of Science and Technology; Office of Water. U.S. Environmental Protection Agency. Washington DC. September 1995. 4–24, 4–25, 10–31.
*EPA. 1996a. Effluent guidelines and standards. Pesticide chemicals. Pesticide chemicals formulating and packaging subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Subpart C; Tables 8 and 10.
EPA. 1996b. Effluent guidelines and standards. Pesticide chemicals. Repackaging of agricultural pesticides performed at refilling establishments. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Subpart E.
*EPA. 1996c. Pesticide chemicals category, formulating, packaging and repackaging effluent limitations guidelines, pretreatment standards, and new source performance standards. Final rule. U.S. Environmental Protection Agency. Federal Register. 60 FR 57518.
EPA. 1996d. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notification. Emergency planning and notification. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A.
*EPA. 1997a. Raw and Processed Food Schedule for pesticide tolerance reassessment. Notice. U.S. Environmental Protection Agency. Federal Register. 62 FR 42020.
EPA. 1997b. Guidelines establishing test procedures for analysis of pollutants and national primary drinking water regulations; flexibility in existing test procedures and streamlined proposal of new test procedures; proposed rule. U.S. Environmental Protection Agency. Federal Register. 62 FR 14976. [List of approved test procedures for pesticides. Code of Federal Regulations 40 CFR 136]. March 28, 1997.
*EPA. 1997c. Method 1657: The determination of organo-phosphorous pesticides in municipal and industrial wastewater. In: EPA methods and guidance for analysis of water. U.S. Environmental Protection Agency. Office of Water, Washington, DC. April 1997. EPA 821-c-97-001.
*EPA. 1998a. Consolidation of certain food and feed additive tolerance regulations. Final rule; technical amendments. U.S. Environmental Protection Agency. Federal Register. 63 FR 2163
EPA. 1998b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.60.
*EPA. 1999a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 180.2
*EPA. 1999b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.173.
*EPA. 1999c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4
*Erney DR, Poole CF, Pawlowski TM. 1997. Matrix-induced peak enhancement of pesticides in gas chromatography: Is there a solution? J High Resolution Chromatog 20(7):375–384.
*Farm chemicals handbook. 1993. Sine C, ed. Willboughby, OH: Meister Publishing Co. C 141.
*FASE. 1996. Exporting risk: pesticide exports from US ports, 1992-1994. Foundation for Advancements in Science and Education. Los Angeles, CA.
*FDA. 1988. FDA pesticide program -Residues in Foods -1987. J Assoc Anal Chem 71(6):156A–174A.
*FDA. 1989. FDA pesticide program - residues in foods -1988. J Assoc Anal Chem 72(5):133A–152A.
*FDA. 1990. Residue in foods: monitoring programs - regulatory monitoring (3rd annual FDA pesticide monitoring program report), 1989. J Assoc Off Anal Chem Int 73(5):127A–146A.
*FDA. 1991. Residue in foods: monitoring programs - regulatory monitoring. (4th annual FDA pesticide monitoring program report), 1990. J Assoc Off Anal Chem Int 74(5):121A–140A.
*FDA. 1992. Residue monitoring, 1991 (5th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem Int 75(5):135A–157A.
*FDA. 1993. Residue monitoring, 1992 (6th annual FDA pesticide residue monitoring program report). J Assoc Off anal Chem Int 76:127A–148A.
*FDA. 1994. Residue monitoring, 1993 (7th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem Int 75(5):163A–185A.
*FDA. 1995. Residue monitoring, 1994 (8th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem Int 78(5):119A–142A.
*FDA. 1997. Pesticide analytical manual. Methods 302 and 304. 3rd ed., vol 1. 1984, 1997 revision. Washington, DC. 302-1 – 304-34.
*FEDRIP. 1998. Ethion. Federal Research in Progress. Dialog Information Service.
*Feiser S. 1983. Acute inhalation toxicity study in rats: Ethion Technical (FMC1240). Unpublished study prepared by Hazelton Laboratories America, Inc. (Study No. 104-214) for FMC Corp. (Study No. A83-873). EPA MRID No. 00163159. (information taken from EPA 1989d)
*Feldman RJ, Maibach HI. 1974. Percutaneous penetration of some pesticides and herbicides in man. Toxicol Appl Pharmacol 28:126–132.4853576
Fenske RA. 1997. Pesticide exposure assessment of workers and their families. Occupational Medicine (Philadelphia) 12(2):221–237.
*Ferreira JR, Silva Fernandes AMS. 1980. Gas-liquid chromatographic determination of organophosphorus insecticide residues in fruits and vegetables. J Assoc Off Anal Chem 63(3):517–22.7430038
*Fitzgerald BB, Costa LG. 1993. Modulation of muscarinic receptors and acetylcholinesterase activity in lymphocytes and in brain areas following repeated organophosphate exposure in rats. Fund Appl Toxicol 20:210–216.
*Fomon, SJ. 1966. Body composition of the infant (Part I: The male reference infant). In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon, SJ, Haschke F, Ziegler EE . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Frank R, Braun HE, Chapman N, . 1991. Degradation of parent compounds of nine organophosphorus insecticides in Ontario surface and ground waters under controlled conditions. 47:(3)374–380.
*Frank R, Braun HE, Holdrinet VH, . 1982. Agriculture and water quality in the Canadian Great Lakes Basin: V. Pesticide use in 11 agricultural watersheds and presence in stream water, 1975-1977. J Environ Qual 11(3):497–505.
*Frawley JP, Fuyat HN, Hagan EC, . 1957. Marked potentiation in mammalian toxicity from simultaneous administration of two anticholinesterase compounds. J Pharmacol Exp Ther 121:96–106.13481831
*Freeman. 1984. Skin sensitization of ethion technical in guinea pigs: study no. A83-1108. Unpublished study prepared by FMC Corp. (information taken from EPA 1989d)
*Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14:515–534.5787520
*Garcia MA, Fernandez MI, Melgar MJ. 1995. Contamination of honey with organophosphorus pesticides. Bull Environ Contam Toxicol 54(6):825–832.7647496
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985a. Pesticides, selected elements and other chemicals in infant and toddler total diet samples October 1978-September 1979. J Assoc Off Anal Chem 68(5):862.4055631
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985b. Pesticides, selected elements and other chemicals in adult total diet samples October 1979-September 1980. J Assoc Off Anal Chem 68(4): 1184–1197.4086442
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, selected elements and other chemicals in infant and toddler total diet samples, October 1980-march 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
*Gelardi RC, Mountford MK. 1993. Infant Formulas: Evidence of the absence of pesticide residues. Regul Toxicol Pharmacol 17:181–192.8484026
*Gianessi LP. 1986. A National Pesticide Usage Data Base. Summary of report submitted to the Office of Standards and Regulations. U.S. Environmental Protection Agency under cooperative agreement CR 8115858-01-0 by Resources for the Future, Feb. 1986. Washington, DC.
*Gilliom RJ. 1985. Pesticides in rivers of the United States. In: National Water Summary 1984- Water Quality Issues(US Geological Survey Water-Supply Paper 2275)85–92.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing evidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glotfelty DE, Majewski MS, Seiber JN. 1990. Distribution of several organophosphorus insecticides and their oxygen analogues in a foggy atmosphere. Environ Sci Technol 24(3):353–357.
*Gore RC, Hannah RW, Pattacini SC, . 1971. Infrared and ultraviolet spectra of seventy-six pesticides. J Assoc Off Anal Chem 54(5):1040–1082.5151664
*Great Lakes Water Quality Board. 1983. Report to the Great Lakes Water Quality Board: An Inventory of Chemical Substances Identified in the Great Lakes ecosystem (Volume 1 - Summary), p. 3.
*Griffini O, Bao ML, Barbieri C, . 1997. Occurrence of pesticides in the Arno River and in potable water-A survey of the period 1992-1995. Bull Environ Contam Toxicol 59:202–209.9211689
*Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: implications for risk assessment. International Life Sciences Institute Press, Washington, D.C.
*Haddad LM. 1994. Organophosphates and other insecticides. In: Goldfrank LR, Flomenbaum NE, Lewin NA, Weisman RS, Howland MA, Hoffman RS, eds: Goldfrank’s toxicologic emergencies. 5th ed. Norwalk, CT: Appleton & Lange, 1076–1087.
*Haque R, Freed VH. 1974. Behavior of pesticides in the environment: Environmental chemodynamics. Res Rev 52:89–116.
Hartke K. 1972. Two-year chronic oral toxicity study with ethion technical in Beagle dogs. Unpublished study prepared by Industrial Bio-Test Laboratories, inc. IBT no: C8705. 83 pp.
*Hayes WJ Jr. 1982. Organic phosphorus pesticides. In: Pesticides studied in man. Baltimore, MD: Williams & Wilkins,, 343–351.
*HazDat. 2000. Ethion. ATSDR’s Hazardous Substance Release & Health Effects Database. www.atsdr.cdc.hazdat.html
*Heikes DL, Craun JC. 1992. Rapid multiresidue procedure for the determination of pesticides in anhydrous lanolin and lanolin-containing pharmaceutical preparations utilizing gel permeation chromatography cleanup with gas chromatographic and mass spectrometric technique. J Agric Food Chem 40:1586–1590.
*Hoberman AM, Christian MS, Christian GD 1983a. Teratogenic potential of ethion technical in pregnant Crl:COBS CD (SD) BR Charles River rats. Unpublished final report dated March 15, 1983 by Argus Research Laboratories, Inc., Horsham, PA for FMC Corp., Princeton, NJ. EPA MRID No. 00131852.
*Hoberman AM, Christian MS, Christian GD, . 1983b. Teratogenic potential of ethion technical administered orally via stomach tube to New Zealand white rabbits: (segment II evaluation) Unpublished final report dated April 7, 1983 by Argus Research Laboratories, Inc., Horsham, PA for FMC Corp., Princeton, NJ. EPA MRID No. 00131853.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*HSDB. 1998. Hazardous substance data bank (Ethion). National Library of Medicine. National Toxicology Program, Bethesda, MD.
*Hundley HK, Cairns T, Luke MA, . 1988. Pesticide residue findings by the Luke Method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J Assoc Off Anal Chem 71(5):875–892.3235407
*IARC. 1987. IARC Monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: an updating of IARC Monographs Volums 1 to 42. Supplement 7. International Agency for Research on Cancer. World Health Organization. Lyon, France. March 10–18, 1987.
*Idaho Department of Health and Welfare. 1999. Ethion. Administrative rules. Air pollution control. 16.01.01. http://www.state.id.us./adm/adminrules/rules/idapa16/16index.htm
IRIS 1998. Integrated Risk Information System. Carcinogenicity Assessment. Ethion. March 1, 1998.
*IRIS. 1999. Ethion. Integrated Risk Information System, U.S. Environmental Protection Agency, http://www.epa.gov/iris/index.html
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. International Register of Potentially Toxic Chemicals. United Nationas Environment Programme. Geneva Switzerland.
*Ivey MC, Mann HD. 1975. Gas-liquid chromatographic determination of ethion, ethion monooxon, and ethion dioxon in tissues of turkeys and cattle. J Agric Food Chem 23(2):319–321.1133307
Ivey MC, Kunz SE, Mann HD. 1975. Ethion, thion monooxon, and ethion dioxon: Residues in the body tissues of turkeys confined in pens on treated soil. J Econ Entomol 68(3):353–4.1141492
*Jeyaratnam J, Maroni M. 1994. Organophosphorous compounds. Toxicology 91(1):15–27.8052981
*Jobsis CT, Zeitlow DC. 1985. Metabolism study of 14C-labeled ethion in lactating goats. Unpublished final report No. 6124-104 dated August 1, 1985 by Hazleton Laboratories America Inc., Madison, WI for FMC Corporation, Princeton, NJ.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Research 190:3–16.6769537
*Johnson PD, Rimmer DA, Brown RH. 1997. Adaptation and application of a multi-residue method for the determination of a range of pesticides, including phenoxy acid herbicides in vegetation, based on high-resolution gel permeation chromatographic clean-up and gas chromatographic analysis with mass-selective detection. J Chromatog 765(1):3–11.
*Johnson RD, Manske DD, New DH, . 1984. Pesticide, heavy metal and other chemical residues in infant and toddler total diet samples. (III) August 1976-September 1977. J Assoc Off Anal Chem 67:145–154.6546565
Jones FW. 1997. The removal of pesticide residues from wool wax by solvent extraction. J Am Oil Chemists’ Society; 74(10):1241–1245.
*Kada T, Moriya M, Shirasu Y. 1974. Screening of pesticides for DNA interactions by rec-assay and mutagenesis testing, and frameshift mutagens detected. Mutat Res 26:243–248.4605088
*Kahn, E. 1976. Pesticide related illness in California farm workers. J Occup Med 18(10):693–696.135080
*KAN-DO Office And Pesticides Team. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready to eat foods. J Assoc Off Anal Chem Int 78(3):614–630.
*Keller JG, Paynter OE. 1958. Final report: subacute feeding studies - rats. Unpublished final report dated June 13, 1958 by Hazelton Laboratories Inc., Falls Church, VA for Niagara Chemical Division, Food Machinery and Chemical Corp. EPA MRID No. 0073077.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
*Komori M, Nishio K, Kitada M . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Wallace Hayes, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: R.S.A. Yang, ed. Toxicology of chemical mixtures. New York, NY: Academic Press.
*Kutz FW, Cook BT. 1992. Selected pesticide residues and metabolites in urine from a survey of the US general population. J Toxicol Environ Health 37:277–291.1404486
*Kutz FW, Yobs AR, Yang HSC. 1976. National pesticide monitoring networks. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Cleveland, OH:CRC Press, 95–136. (in progress)
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: implications for practice. Pediatric Clinics of North America 44:55–77.9057784
*Leffingwell JT, Spear RC, Jenkins D. 1975. The persistence of ethion and zolone residues on grape foliage in the central valley of California. Arch Environ Contam Toxicol 3(1):40–54.1130830
*Lehotay SJ. 1997. Supercritical fluid extraction of pesticides in foods. J Chromatog 785:289–312.
*Lehotay SJ, Valverde-Garcia A. 1997. Evaluation of different solid-phase traps for automated collection and clean-up in the analysis of multiple pesticides in fruits and vegetables after supercritical fluid extraction. J Chromatog A 765:69–84.9129302
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Lewis RG, Lee Jr. RE. 1976. Air pollution from pesticides: Sources, occurrence, and dispersion. In: Lee RE Jr., ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 5–50.
*Lino CM, da Silveira MI. 1994. Chlorpyrifos, ethion, fenitrothion, and methidathion residues in chickens. Bull Environ Contam Toxicol 52(3):425–431.8142715
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Lopez-Avila V, Young R, Beckert WF. 1997. On-line determination of organophosphorus pesticides in water by solid-phase microextraction and gas chromatography with thermionic-selective detection. J High Resolution Chromatog 20(9):487–492.
*Luke MA, Masumoto HT, Cairns T. 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke multiresidue methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71(2):415–420 3384794
*MacNeil JD, Hikichi M. 1976. Degradation of endosulfan and ethion on pears and pear and grape foliage. J Agric Food Chem 24(3):608–611.1270675
*Mahajna M, Quistad GB, Casida JE. 1996. S-methylation of O,O-dialkyl phosphorodithioic acids: O,O, S-trimethyl phosphorodithioate and phosphorothiolate as metabolites of dimethoate in mice. Chem Res Toxicol 1202–1206.8902277
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*Merck. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck and Company, Inc., 590.
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
*Miles JRW, Harris CR. 1978a. Insecticide residues in water, sediment, and fish of the drainage system of the Holland Marsh, Ontario, Canada, 1972-75. J Econ Entomol 71:125–131.627669
*Miles JRW, Harris CR. 1978b. Insecticide residues in organic soils of six vegetable growing areas in southwestern Ontario, 1976. J Environ Sci Health B. 13(3):199–209.
*Miles JRW, Harris CR, Moy P. 1978. Insecticide residues in organic soil of the Holland Marsh, Ontario, Canada, 1972-75. J Econ Entomol 71:97–101.
*Miles JRW, Tu CM, Harris CR. 1979. Persistence of eight organophosphate insecticides in sterile and non-sterile mineral and organic soils. Bull Environ Contam Toxicol 22:312–318.465800
*Minyard JP, Roberts WE. 1991. Chemical contaminants monitoring: State findings on Pesticide Residues in Foods - 1988 and 1989. J Assoc Off Anal Chem 74:(3):438–449.1874687
*Mithyantha MS, Agnihothrodu. 1984. Persistence of some insecticides and fungicides in soils. Pestic Environ Proc Natl Semin, 108–115.
*Morrow L. 1985a. Twenty-four month combined chronic oral toxicity and oncogenicity study in rats utilizing ethion (FMC 1240) technical. Unpublished final report dated August 1985 by American Biogenics Corporation, Decatur, IL for FMC Corporation, Princeton, NJ. EPA MRID No. 00148991.
*Morrow. L. 1985b. Lifespan oncogenicity study in mice utilizing ethion (FMC 1240) technical: Unpublished final report dated July 30, 1985 by American Biogenics Corporation, Decatur, IL for FMC Corporation, Princeton, NJ. EPA MRID No. 00148989.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clinical Pharmacokinetics 5:485–527.7002417
Mosha RD, Gyrd-Hansen N. 1990. Toxicity of ethion in goats. Vet Hum Toxicol 32(1):6–8.2301152
*Mosha RD, Gyrd-Hansen N, Nielsen P. 1990a. Distribution and elimination of 14C-ethion in laying hens and eggs after oral exposure. Bull Environ Contam Toxicol 45(3):375–381.2257332
*Mosha RD, Gyrd-Hansen N, Nielsen P. 1990b. Fate of ethion in goats after intravenous, oral and dermal administration. Pharmacol Toxicol 67:246–251.2255681
*Mosha RD, Gyrd-Hansen N, Nielsen P. 1991. Residues of ethion in milk after intravenous, oral, and dermal administration to goats. J Agric Food Chem 39(2):396–399.
*Muacevic G. 1973. Acute toxicity and cholinesterase inhibition in vivo of bromophos-ethyl. Toxicol Appl Pharmacol 25:180–189.4715482
Nagayama T. 1997. Transference of organophosphorus pesticides to wine from fruits during the process of making fruit wine. J Food Hyg Soc Jpn 38(4):270–274.
Nagayama T, Kobayashi M, Ito M, . 1997. Pesticide residues in crops labeled cultivation with reduced application of pesticide (1988.4-1994.3) J Food Hyg Soc Jpn 38(6):464–469.
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Research Council. Board of Environmental Studies and Toxicology. Committee on Biological Markers. 15–35.
*Needham . 1990. A program for assessing background levels of 52 organic toxicants in the US population. The Fifth International Conference on Indoor Air Quality and Climate, 453–457.
New Jersey Department of Environmental Protection. 1993. Ethion. DEP Units & Program Areas. Division of water quality. Rules and regulations. http://www.state.nj.us/dep/dwq
Nigg NH, Allen JC, Brooks RF, . 1977. Dislodgeable residues of ethion in Florida citrus and relationships to weather variables. Arch Environ Contam Toxicol 6:257–267.901006
*Nigg HN, Stamper JH, Easter E, . 1992. Field evaluation of coverall fabrics: Heat stress and pesticide penetration. Arch Environ Contam Toxicol 23:281–288.1456772
Nigg NH, Stamper JH, Mahon WD. 1990. Handgun applicator exposure to ethion in Florida citrus. Bull Environ Contam Toxicol 45:463–468.2257343
*Nigg HN, Stamper JH, Mallory LL. 1993. Quantification of human exposure to ethion using saliva. Chemosphere 26(5):897–906.
*Nigg HN, Stamper JH, Queen RM, . 1988. Ethion distribution in Florida valencia oranges. Bull Environ Contam Toxicol 41(1):151–158.3179522
*NIOSH. 1992. NIOSH recommendations for Occupational Safety and Health. Compendium of Policy Documents and Statements. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control. National Institute for Occupational Safety and Health. Publication NO. 92-100. Cincinnati, Ohio.
NIOSH. 1994. NIOSH manual of analytical methods 4th edition. Method 5600. U.S. Department of Health and Human Services, Public Health Service, Center for Disease Control and Prevention, National Institute for Occupational Safety and Health.
*NIOSH. 1999. Pocket guide to chemical hazards. Ethion. U.S. Department of Health and Human Services, Public Health Service, Center for Disease Control and Prevention, National Institute for Occupational Safety and Health.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council, Washington DC: National Academy Press.
*NTP. 1998. Eighth report on carcinogens. 1998 Summary. National Toxicology Program. U.S. Department of Health and Human Services. Public Health Services.
*OSHA. 1989. Occupational Safety and Health Administration. 29 CFR Part 1910. Air Contaminants; Final Rule. Occupational Safety and Health Administration. Department of Labor. Federal Register. 54 FR 2644, 2646, 2648-2649, and 2655.
*OSHA. 1993. Air Contaminants. Occupational Safety and Health Administration. Federal Register. 58 FR 35338-35340. Final Rule. June 30, 1993.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: Saunders, 222–238.
*Palazzolo RJ. 1970. A study on the effects of ethion on plasma and erythrocyte cholinesterase activity in human subjects during subacute administration. Unpublished report dated December 23, 1970 by Industrial Bio-Test Laboratories for Niagara Chemical Division, FMC Corporation. EPA MRID No. 00073157.
*Pearce KL, Trenerry VC, Were S. 1997. Supercritical fluid extraction of pesticide residues from strawberries. J Agric Food Chem 45(1):153–157.
Pedersen M. 1998. Aqueous and solid organophosphate pesticide formulations with improved properties as to stability, toxicity and smell. Application: Denmark WO98/07317,26 Feb 1998: AOIN25/22,25/32,57/10,25/28. Denmark Patent WO98/07317, issued 26 Feb 1997.
*Phillips LJ, Birchard GF. 1991. Regional Variations in Human Toxics Exposure in the USA: An Analysis Based on the National Human Adipose Tissue Survey. Arch Environ Contam Toxicol 21:159–168.1958071
*Planas C, Caixach J, Santos FJ, . 1997. Occurrence of pesticide in Spanish surface waters. Analysis by high resolution gas chromatography coupled to mass spectrometry. Chemosphere 34(11):2393–2406.
*Racke KD. 1992. Degradation of organophosphorous insecticides in environmental matrices. In: Chambers JE, Levi PE, eds. Organophosphates - Chemistry, Fate, and Effects. Academic Press, 47–78.
*Rao SLN, McKinley WP. 1969. Metabolism of organophosphorus insecticides by liver homogenates from different species. Canadian Journal of Biochemistry 47(12):1155–1159.4391423
Rhode Island Department of Environmental Management. 1992. Ethion. Regulations and air resources. http:/www.sec.state.ri.us/dem/ (http://www.sec.state.ri.us/dem/)
*Roberts NL, Phillips CNK, Gopinath C, . 1986. Acute delayed neurotoxicity study with FMC 1240 in the domestic hen: Unpublished study by Huntingdon Research Centre Ltd., Huntingdon, Cambridgeshire, England for FMC Corp., Princeton NJ. EPA MRID No. 00158376.
*Roy RR, Albert RH, Wilson P, . 1995. US Food and Drug Administration Pesticide Program: Incidence/level monitoring of domestic and imported pears and tomatoes. J of AOAC International 78(4):930–940.
*Schattenburg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J of AOAC International 75:925–933.
Schoen SR, Winterlin WL. 1987. The effects of various soil factors and amendments on the degradation of pesticide mixtures. J Environ Sci Health B 22(3):347–377.3655189
*Schomberg CJ, Glotfelty DE, Seiber JN. 1991. Pesticide occurrence and distribution in fog collected near Monterey, California. Environ Sci Technol 25:155–160.
*Selim S. 1985a. Absorption, distribution and excretion studies of ethion in the rat. Unpublished final report dated December 10, 1985 by Biological Test Center, Irvine CA for FMC Corporation, Princeton NJ.
Selim S. 1985b. Analysis of metabolites in urine of rats dosed with ethion. Unpublished interim report dated December 13, 1985 by Biological Test Center, Irvine CA, for FMC Corporation, Princeton, NJ.
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Chapter 6 in Handbook of Physiology: Endocrinology V (Creep RO, Astwood EB (eds); Geiger SR (executive ed.). American Physiological Society, Washington DC.
*Sharom MS, Miles JRW, Harris CR, . 1980a. Persistence of 12 insecticides in water. Water Res 14:1089–1093.
*Sharom MS, Miles JRW, Harris CR, . 1980b. Behaviour of 12 insecticides in soil and aqueous suspensions of soil and sediment. Water Res 14:1095–1100.
*Sherman JC, Nevin TA, Lasater JA. 1974. Hydrogen sulfide production from ethion by bacteria in lagoonal sediments. Bull Environ Contam Toxicol 12(3):359–365.4433881
*Shirashu Y, Moriya M, Kato K, . 1976. Mutagenicity screening of pesticides in the microbial system. Mutat Res 40:19–30.814455
*Sicbaldi F, Sarra A, Copeta GL. 1997. Diatomaceous earth-assisted extraction for the multiresidue determination of pesticides. J Chromatog 765(1):23–30.
*Singh AK, Hewetson DW, Jordon KC, . 1986. Analysis of organophosphorus insecticides in biological samples by selective ion monitoring gas chromatography-mass spectrometry. J Chromatog 369:83–96.3793834
*Skopec ZV, Clark R, Harvey PMA, . 1993. Analysis of organophosphorus pesticides in rice by supercritical fluid extraction and quantitation using an atomic emission detector. J Chromatog Sci 31:445–449.8270649
*Sobti RC, Krishan A, Pfaffenberger CD. 1982. Cytokinetic and cytogenetic effects of some agricultural chemicals on human lymphoid cells in vitro: organophosphates. Mutat Res 102:89–102.6981766
South Dakota Department of Environment and Natural Resources. 1998. Drinking water regulations. Drinking water standards. http://www.state.sd.us./state/executive/denr/denr.html
*SRC. 1995. Atmospheric oxidation program. Syracuse Research Corporation. Environmental Science Center. Syracuse, NY.
*SRI International. 1991. 1991 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International. 844–845.
*SRI International. 1992. 1992 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International. 833.
*SRI International. 1993. 1993 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International. 811.
*SRI International. 1995. 1995 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International. 800.
*SRI International. 1996. 1996 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International.
*SRI International. 1997. 1997 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International. 793.
*Swann RL, Laskowski PJ, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
*Taylor P, Li Y, Camp S, . 1993. Structure and regulation of expression of the acetylcholinesterase gene. Chem Biol Interactions 87:199–207.
*Termonia A, Termonia M. 1997. Full scan gc-ms quantitation of pesticides in spring water at the 10 ppt level using large volume on-column injection. Hrc J High Resolution Chromatog 20(8):447–450.
*Thomas RG. 1990. Volatilization of water. In: Lyman WJ, Reehl WF, and Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. Washington, DC: American Chemical Society. 15-16–15-17.
*Thompson NP, Brooks RF. 1976. Disappearance of dislodgable residues of five organophosphate pesticides on citrus leaves and fruit during dry and wet weather in Florida. Arch Environ Contam Toxicol 5(1):55–61.1015863
*Tomlin C. 1994. Ethion. In: The pesticide manual: Incorporating the agrochemicals handbook. 10th ed. British Crop Protection Council Publications and The Royal Society of Chemistry. 407–408.
*Tomlin C. 1997. Ethion. In: The pesticide manual: A world compendium. 11^th^ ed. British Crop Protection Council Publications and the Royal Society of Chemistry. 480–482.
*Torres CM, Pico Y, Redondo MJ, Manes J. 1996. Matrix solid-phase dispersion extraction procedure for multiresidue pesticide analysis in oranges. J Chromatogr 719(1):95–103.
*U.S. Congress. 1977. Federal water pollution control act, as amended by the clean water act of 1977. U.S. Congress. Public Law 95-217, December 28, 1977.
USDA. 1995a. Federal Seed Act. Importation of seed and screening under the federal seed act. Animal and plant health inspection service. U.S. Department of Agriculture. Code of Federal Regulations. 7 CFR 361.
USDA. 1995b. Federal Seed Act. Federal seed act regulations. Labeling treated seed. U.S. Department of Agriculture. Code of Federal Regulations. 7 CFR 201.31a.
*USGS. 1992. Pesticide 1992 annual use map: Ethion. United States Geological Survey. http://ca.water.usgs.gov/pnsp/use92/ethion.html accessed 12/1/99.
*Valor I, Molto JC, Apraiz D, . 1997. Matrix effects on solid-phase microextraction of organophosphorus pesticides from water. J Chromatog A 767:195–203.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. European Journal of Biochemistry 238:476–483.8681961
*Waters MD, Simmon VF, Mitchell AD, . 1980. An overview of short term tests for the mutagenic and carcinogenic potential of pesticides. J Environ Sci Health B15(6):867–906.
*Weiner M. 1985a. Twenty-one day repeated dose dermal toxicity study in rabbits with FMC 1240 technical (ethion): study no. A84-1369. Unpublished study prepared by FMC Corp. EPA MRID No, 00155498. (information taken from EPA 1989d)
*Weiner M. 1985b. Twenty-one day repeated dose dermal toxicity study in male rabbits with FMC 1240 technical (ethion): study no. A84-1502. Unpublished study prepared by FMC Corp. EPA MRID No. 00155499. (information taken from EPA 1989d)
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J. of Pediatrics 32a:10–18.
*Whitmore RW, Immerman FW, Camann DE, . 1994. Non-occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contam Toxicol 26:47–59.8110023
WHO. 1996. Guidelines for drinking-water quality. Second Edition. Volume 2. Health criteria and other supporting information. World Health Organization. International Programme on Chemical Safety. Geneva.
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: C.L. Comar and Felix Bronner, eds. Mineral metabolism: An advanced treatise, Volume II - the elements part A. New York, NY: Academic Press.
*Winterlin WL, Schoen SR, Mourer CR. 1984. Disposal of Pesticide Wastes in Lined Evaporation Beds. In: Treatment and Disposal of Pesticide Wastes. American Chemical Society (ACS) Symposium Series, Krueger RF and Seiber JN (editors), 97–116.
*Wisconsin Department of Natural Resources. 1997. Ethion. Regulation & Licensing. Environmental rules. Environmental Protection Air Pollution Control. Chs 400-499. http://www.dnr.state.wi.us/org/aw/air/index.htm
*Wojeck GA, Nigg HN. 1980. Worker exposure to pesticides in Florida citrus operations. Proceedings of the Florida State Horticultural Society 93:60–62.
*Wojeck GA, Nigg HN, Stamper JH, . 1981. Worker exposure to ethion in Florida citrus. Arch Environ Contam Toxicol 10:725–735.7325691
*Wolfe HR, Staiff DC, Armstrong JF. 1978. Exposure of formulating plant workers to ethion and malathion. Bull Environ Contam Toxicol 20:778–781.749976
*Yess NJ, Gunderson EL, Roy RR. 1993. Chemical contaminants monitoring: U.S. food and drug administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J Assoc Off Anal Chem Int 76(3):492–507.
*Yess NJ, Houston MG, Gunderson EL. 1991. Food and drug administration pesticide residue monitoring of foods: 1978-1982. J Assoc Off Anal Chem 74(2):265–272.2050608
*Youngren SH, Rachman NJ, Turnbull D. 1991. Risk Assessment for children playing on lawns treated with a pesticide. The analysis, communication and perception of risk. Garrick BJ, Gekler WC, eds.. New York: Plenum Press, 77–86.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372