# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of ethion is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of ethion is located in Table 3-2.

Table 3-1 Chemical Identity of Ethion

Characteristic | Information | Reference
Chemical name | Ethion | HSDB 1998
Synonym(s) | Phosphorodithioic acid; S,S’-methylene O,O,O’,O’-tetraethyl ester; ethyl methylene phosphorodithioate; O,O,O’,O’-tetraethyl S,S’-methylenediphosphorodithioate; bis[-(diethoxyphosphinothioyl)mercapto]methane | Merck 1989
Registered trade name(s) | NIA1240, Ethanox, Nialate, RP8167, Rodocide, and others | HSDB 1998
Chemical formula | C_9_H_22_O_4_P_2_S_4_ | Merck 1989
Chemical structure | [image]
Identification numbers:
CAS Registry | 563-12-2 | HSDB 1998
NIOSH RTECS | TE455000 | HSDB 1998
EPA Hazardous Waste | 7800010 | HSDB 1998
OHM/TADS/DOT/UN/NA/IMCO | IMO 6.1; UN 3018; NA 2783 | HSDB 1998
HSDB | 399 | HSDB 1998
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Ethion

Property | Information | Reference
Molecular weight | 384.48 | Merck 1989
Color | White/colorless to amber | Tomlin 1994
Physical state | Liquid | Tomlin 1994
Melting point | −12 to −13 | Merck 1989
Boiling point | 164–165 at 0.3 mm Hg | EPA 1989b
Density at 19 °C | 1.220 at 20 °C | Merck 1989
Odor | Odorless in pure form; technical product has a disagreeable odor | HSDB 1998
Odor threshold:
Water | No data
Air | No data
Solubility:
Fresh water at 25 °C | 0.6 mg/L | Sharom et al. 1980a
Salt water at 25 °C | No data
Organic solvent(s) | Xylene, chloroform, acetone, kerosene plus 1% methyl ethyl ketone, benzene | Merck 1989
Organic solvent(s) | Most organic solvents | HSDB 1998
Partition coefficients:
Log K_ow_ | 5.073 | Bowman and Sans 1983
Log K_oc_ | 4.189 (average in four soils) | HSDB 1998
Log K_oc_ | 3.810 (organic soil) | Sharom et al.1980b
Log K_oc_ | 3.936 (beverly sandy loam)
Log K_oc_ | 4.004 (plainsfield sand)
Vapor pressure at 20 °C | 1.5×10^−6^ mm Hg | EPA 1989b; Merck 1989
Henry’s law constant: | 6.9×10^−7^ atm m^3^/mole | HSDB 1998
at 25 °C
Hydrolysis half-life
30 °C (sterile water) | pH 4 & 7 146 days | Dierberg and Pfeuffer 1983
30 °C (sterile water) | pH 8 62 days
30 °C (sterile water) | pH 10 1 day
30 °C (non-sterile drainage water) | 26 days
25 °C (water with 1% ethanol) | pH 4.5 99 weeks | Chapman and Cole 1982
25 °C (water with 1% ethanol) | pH 5 63 weeks
25 °C (water with 1% ethanol) | pH 6 58 weeks
25 °C (water with 1% ethanol) | pH 7 25 weeks
25 °C (water with 1% ethanol) | pH 8 8.4 weeks
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | May burn but does not ignite readily | HSDB 1998
at 25 °C
Reactivity | Hydrolyzed by acids and alkalies | Tomlin 1994
Reactivity | Emits toxic oxides of sulfur and phosphorous (T≥150°C) | Sax 1984
Reactivity | Slowly oxidized in air | Tomlin 1994
Conversion factors (25 °C) | 1 ppm = 15.7 mg/m^3^ | Calculated
Conversion factors (25 °C) | 1 mg/m^3^ = 0.064 ppm
Explosive limits | Tends to decompose with violence above 150 °C | HSDB 1998