# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Ethion Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Ethion
CAS number: | 563-12-2
Date: | June 14, 2001
Profile status: | Third Draft Post-Public Comment
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 24
Species: | Dog
MRL: [underlined: 0.002] | [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Bailey DE. 1988. 90-day subchronic toxicity study of ethion technical in dogs. Unpublished revised final report dated June 21, 1988 by Hazelton Laboratories America, Inc., Vienna VA, for FMC Corporation, Princeton NJ. Hazelton Study No. 104-229, FMC Study No. A86-1990, EPA MRID No. 40773301. [Available from EPA. Write to FOI, EPA, Washington, DC 20460]

[underlined: Experimental design]: See MRL Worksheet for intermediate-duration oral exposure, page A-5.

[underlined: Effects noted in study and corresponding doses]: See MRL Worksheet for intermediate-duration oral exposure, page A-5.

[underlined: Dose end point used for MRL derivation]: 0.06 mg/kg/day; brain acetylcholinesterase inhibition

[x] NOAEL [ ]LOAEL

[underlined: Uncertainty factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [x] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

The acute oral MRL for ethion is derived as follows:

MRL = NOAEL ÷ UF MRL = 0.06 mg / kg / day ÷ 30 MRL = 0.002 mg / kg / day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Dose was calculated using mean daily compound consumption reported in the study (Table 5).

[underlined: Was a conversion used from intermittent to continuous exposure? If so, explain]: Not applicable

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable

[underlined: Other additional studies or pertinent information that lend support to this MRL]: This MRL should be protective against health effects in individuals potentially exposed to ethion at hazardous waste sites. A study in volunteers (Palazollo 1970) has determined the sensitivity of humans to the effects of ethion on blood cholinesterase activities. A group of six male volunteers were given ethion in corn oil solutions in three divided doses (9:00 a.m., noon, and 5:00 p.m.) of 0.05, 0.075, 0.1, and 0.15 mg/kg/day via gelatin capsule. Subjects received 0.05, 0.075, and 0.1 mg/kg/day for 3 weeks each and then 0.15 mg/kg/day for 3 days. No adverse clinical signs (blood pressure, pulse rate, pupil size, light reflex, eye accommodation, chest sound, muscle tone, knee jerk, tongue tremor and finger tremor) or effects on erythrocyte acetylcholinesterase were observed at any time during the study. Absorption of ethion by the volunteers was confirmed by a decrease in plasma cholinesterase levels. While no effect on plasma cholinesterase was observed at the 0.05 mg/kg/day dose level, a 16% decrease was seen in the 0.075 mg/kg/day group. Decreases of 23 and 31% were seen in the 0.1 and 0.15 mg/kg/day groups.

The NOAEL of the Bailey study for inhibition of brain acetylcholinesterase was adjusted by a factor of 10 for human variability and a factor of 3 for extrapolation of an animal study to humans. A factor of 3 was used for extrapolation rather than the full uncertainty factor of 10 because the results of the Palazzollo (1970) study indicated that dogs appear to be at least as sensitive to the neurological effects of ethion as humans when exposed to comparable doses.

The MRL value of 0.002 mg/kg/day for intermediate-duration oral exposure to ethion was extended to acute-duration oral exposure based on the toxicokinetics of ethion. Cholinesterase inhibition occurs quickly and there are no indications of progressive inhibition over time at a given dose in either the Palazzollo (1970) study in humans or the Bailey (1988) study in dogs. A similar lack of progression of inhibition was seen in 2-year studies in rats and mice where brain and erythrocyte acetylcholinesterase and plasma cholinesterase were measured at 6-month intervals (Morrow et al. 1985a, 1985b). The toxicity database indicates no change in ethion toxicity over time, i.e., toxicity is dependent on the dose, not the duration of exposure. Because the toxicological effects of ethion are due to a series of repeated acute exposures, the intermediate-duration oral MRL should be protective for this endpoint for acute exposure durations.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney

## Ethion Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Ethion
CAS number: | 563-12-2
Date: | June 14, 2001
Profile status: | Third Draft Post-Public Comment
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Key to figure: | 24
Species: | Dog
MRL: [underlined: 0.002] | [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Bailey DE. 1988. 90-day subchronic toxicity study of ethion technical in dogs. Unpublished revised final report dated June 21, 1988 by Hazelton Laboratories America, Inc., Vienna VA, for FMC Corporation, Princeton NJ. Hazelton Study No. 104-229, FMC Study No. A86-1990, EPA MRID No. 40773301. [Available from EPA. Write to FOI, EPA, Washington, DC 20460]

[underlined: Experimental design]: The purpose of this study was to evaluate the subchronic toxicity of Ethion Technical when administered orally to dogs for 13 weeks. Groups of Beagle dogs (n=4/sex/group, 20-28 weeks old) received ethion (purity 93.4%)in the diet at target concentrations of 0, 0.5, 2.5, 25.0, and 300 ppm for 90 days. Food was available for 2 hours a day, water was available ad libitum. The average compound consumed was 0, 0.01, 0.06, 0.71 and 6.9 mg/kg/day for males and 0, 0.012, 0.07, 0.71 and 8.25 mg/kg/day for females. All dogs were observed twice daily for mortality and moribundity. Animals were observed once daily for clinical signs. Body weights were recorded during acclimation and quarantine, on day 0 (one day prior to treatment initiation), and weekly thereafter. Food consumption was measured weekly. Detailed physical exams were performed at each weighing interval. Ophthalmoscopic examinations were performed prior to initiation and during week 13. Clinical pathology parameters were evaluated for all dogs prior to initiation of treatment (day -16) and during weeks 5, 9, and 13 and included the following: cholinesterase (plasma, erythrocyte, brain) activity, hematology (leukocyte count, erythrocyte count, hemoglobin, corrected leukocyte count, hematocrit, platelet count, differential leukocyte count), and clinical chemistry (sodium, potassium, chloride, total protein, albumin, calcium, phosphorus, total bilirubin, urea nitrogen, creatinine, glucose, alanine aminotransferase, aspartate aminotransferase, globulin). All surviving animals were sacrificed following the 13-week treatment period. Necropsies were performed, terminal body weights taken, and liver (with drained gallbladder), kidneys, testes (with epididymides), thyroid (with parathyroid) and brain weights were taken. Histopathological examination of the following tissues was conducted: lesions, brain (with medulla/pons, cerebellar cortex, and cerebral cortex), gallbladder, pituitary, thyroid (parathyroid), thymus, lungs, trachea, heart, bone (femur), salivary glands (mandibular), bone marrow (sternum), kidneys, uterus, adrenals, liver, spleen, pancreas, testes (with epididymides), ovaries, aorta, esophagus, stomach, duodenum, jejunum, ileum, colon, cecum, rectum, urinary bladder, mesenteric lymph node, sciatic nerve, spinal cord (cervical, thoracic, lumbar), skin, mammary gland, and eyes.

[underlined: Effects noted in study and corresponding doses]: One female dog in the 8.25 mg/kg/day group was sacrificed on day 90 (one day before schedule). Clinical signs exhibited by this animal prior to sacrifice included emesis, dehydration, and thin body mass. All other animals survived until terminal sacrifice. In the highest dose group (6.9 mg/kg/day for males, 8.25 mg/kg/day for females) clinical signs included miosis (all animals), emesis (all animals), dehydration (3M, 2F), salivation (2M, 2F), and tremors (3M, 4F). Animals in this group appeared to be in generally poor condition at the end of the study. Erythrocyte acetylcholinesterase was strongly inhibited at weeks 5 (94%M, 96%F), 9 (95%M, 93%F), and 13 (94%M, 93%F) in the highest dose groups, but not in any of the other groups. Mean percent brain acetylcholinesterase activity inhibition at termination was 64% in males and 61% in females at the highest dose. Male brain acetylcholinesterase was inhibited 23% at 0.71 mg/kg/day but no inhibition of brain acetylcholinesterase occurred in females at this dose. Plasma cholinesterase inhibition was dose-related in both males and females. No significant differences in absolute organ weights were observed between treated and control animals. No compound-related histopathological effects were observed in any organ, including brain, sciatic nerve and spinal cord. The no-observed-adverse-effect level for inhibition of brain acetylcholinesterase is 0.06 mg/kg/day.

Cholinesterase Inhibition vs. Control at 13 Weeks (In Percentages)

Dose (mg/kg/day) | Plasma cholinesterase | Erythrocyte acetylcholinesterase | Brain acetylcholinesterase
0.01 (M) | 3 | 4 | 10
0.012 (F) | 5 | 0 | 0
0.06 (M) | 15^*^ | 5 | 1
0.07 (F) | 13 | 0 | 0
0.71 (M) | 58^*^ | 12 | 23^*^
0.71 (F) | 52^*^ | 5 | 2
6.9 (M) | 84^*^ | 94^*^ | 64^*^
8.25 (F) | 84^*^ | 93^*^ | 61^*^

* significantly different from control (p<0.05).

[underlined: Dose end point used for MRL derivation]: 0.06 mg/kg/day; brain acetylcholinesterase inhibition

[x] NOAEL [ ]LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [x] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

The intermediate oral MRL for ethion is derived as follows:

MRL = NOAEL ÷ UF MRL = 0.06 mg / kg / day ÷ 30 MRL = 0.002 mg / kg / day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] If so, explain: Dose was calculated using mean daily compound consumption reported in the study (Table 5).

[underlined: Was a conversion used from intermittent to continuous exposure? If so, explain]: Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: This MRL should be protective against health effects in individuals potentially exposed to ethion at hazardous waste sites. A study in volunteers (Palazollo 1970) has determined the sensitivity of humans to the effects of ethion on blood cholinesterase activities. A group of six male volunteers were given ethion in corn oil solutions in 3 divided doses (9:00 a.m., noon, and 5:00 p.m.) of 0.05, 0.075, 0.1, and 0.15 mg/kg/day via gelatin capsule. Subjects received 0.05, 0.075, and 0.1 mg/kg/day for 3 weeks each and then 0.15 mg/kg/day for 3 days. No adverse clinical signs (blood pressure, pulse rate, pupil size, light reflex, eye accommodation, chest sound, muscle tone, knee jerk, tongue tremor and finger tremor) or effects on erythrocyte acetylcholinesterase were observed at any time during the study. Absorption of ethion by the volunteers was confirmed by a decrease in plasma cholinesterase levels. While no effect on plasma cholinesterase was observed at the 0.05 mg/kg/day dose level, a 16% decrease was seen in the 0.075 mg/kg/day group. Decreases of 23 and 31% were seen in the 0.1, and 0.15 mg/kg/day groups.

The NOAEL of the Bailey study for inhibition of brain acetylcholinesterase was adjusted by a factor of 10 for human variability and a factor of 3 for extrapolation of an animal study to humans. A factor of 3 was used for extrapolation rather than the full uncertainty factor of 10 because the results of the Palazzollo (1970) study indicated that dogs appear to be at least as sensitive to the neurological effects of ethion as humans when exposed to comparable doses.

The MRL value of 0.002 mg/kg/day for intermediate-duration oral exposure to ethion was extended to acute-duration oral exposure based on the toxicokinetics of ethion. Cholinesterase inhibition occurs quickly and there are no indications of progressive inhibition over time at a given dose in either the Palazzollo (1970) study in humans or the Bailey (1988) study in dogs. A similar lack of progression of inhibition was seen in 2-year studies in rats and mice where brain and erythrocyte acetylcholinesterase and plasma cholinesterase were measured at 6 month intervals (Morrow et al. 1985a, b). The toxicity database indicates no change in ethion toxicity over time, i.e. toxicity is dependent on the dose, not the duration of exposure. Because the toxicological effects of ethion are due to a series of repeated acute exposures, the intermediate-duration oral MRL should be protective for this endpoint for acute exposure durations.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney

## Ethion Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Ethion
CAS number: | 563-12-2
Date: | June 14, 2001
Profile status: | Third Draft Post-Public Comment
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Key to figure: | 24
Species: | Dog
MRL: [underlined: 0.0004] | [x] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Bailey DE. 1988. 90-day subchronic toxicity study of ethion technical in dogs. Unpublished revised final report dated June 21, 1988 by Hazelton Laboratories America, Inc., Vienna VA, for FMC Corporation, Princeton NJ. Hazelton Study No. 104-229, FMC Study No. A86-1990, EPA MRID No. 40773301. [Available from EPA. Write to FOI, EPA, Washington, DC 20460]

[underlined: Experimental design]: See MRL Worksheet for intermediate-duration oral exposure, page A-5.

[underlined: Effects noted in study and corresponding doses]: See MRL Worksheet for intermediate-duration oral exposure, page A-5.

[underlined: Dose end point used for MRL derivation]: 0.06 mg/kg/day; brain acetylcholinesterase inhibition

[x] NOAEL [ ]LOAEL

[underlined: Uncertainty factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [x] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[ ] 1 [x] 5 [ ] 10 (Modifying Factor)

The chronic oral MRL for ethion is derived as follows:

MRL = NOAEL ÷ ( UF * MF ) MRL = 0.06 mg / kg / day ÷ ( 30 * 5 ) MRL = 0.0004 mg / kg / day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Dose was calculated using mean daily compound consumption reported in the study (Table 5).

[underlined: Was a conversion used from intermittent to continuous exposure? If so, explain]: Not applicable

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable

[underlined: Other additional studies or pertinent information that lend support to this MRL]: This MRL should be protective against health effects in individuals potentially exposed to ethion at hazardous waste sites. A study in volunteers (Palazollo 1970) has determined the sensitivity of humans to the effects of ethion on blood cholinesterase activities. A group of six male volunteers were given ethion in corn oil solutions in 3 divided doses (9:00 a.m., noon, and 5:00 p.m.) of 0.05, 0.075, 0.1, and 0.15 mg/kg/day via gelatin capsule. Subjects received 0.05, 0.075, and 0.1 mg/kg/day for 3 weeks each and then 0.15 mg/kg/day for 3 days. No adverse clinical signs (blood pressure, pulse rate, pupil size, light reflex, eye accommodation, chest sound, muscle tone, knee jerk, tongue tremor and finger tremor) or effects on erythrocyte acetylcholinesterase were observed at any time during the study. Absorption of ethion by the volunteers was confirmed by a decrease in plasma cholinesterase levels. While no effect on plasma cholinesterase was observed at the 0.05 mg/kg/day dose level, a 16% decrease was seen in the 0.075 mg/kg/day group. Decreases of 23 and 31% were seen in the 0.1, and 0.15 mg/kg/day groups.

The NOAEL of the Bailey study for inhibition of brain acetylcholinesterase was adjusted by a factor of 10 for human variability and a factor of 3 for extrapolation of an animal study to humans. A factor of 3 was used for extrapolation rather than the full uncertainty factor of 10 because the results of the Palazzollo (1970) study indicated that dogs appear to be at least as sensitive to cholinesterase inhibition by ethion as humans when exposed to comparable doses. An additional modifying factor of 5 was applied to the chronic duration to protect against possible long-term effects, seen in structurally-related cholinesterase inhibitors, which might be the result of mechanisms other than cholinesterase inhibition, and to protect against possible susceptibility in children.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney