# CHAPTER 8 REFERENCES

ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Ahmed FE, Hattis D, Wolke RE, . 1993. Risk assessment and management of chemical contaminants in fishery products consumed in the USA. J Appl Toxicol 13(6):395–410.8288843
Akubue PI, Stohs SJ. 1992. Endrin-induced production of nitric oxide by rat peritoneal macrophages. Toxicol Letters 62:311–316.
Alawi MA, Ammari N, Al-Shuraiki. 1992. Organochlorine pesticide contaminations in human milk samples from women living in Amman, Jordan. Arch Environ Contam Toxicol 23:235–239.1514844
Alawi MA, Tamimi S, Jaghabir M. 1999. Storage of organochlorine pesticides in human adipose tissues of Jordanian males and females. Chemosphere 38(12):2865–2873.10214717
Ali SS, Shakoori R. 1993. Short-term toxicity of endrin in Sprague Dawley rats: Biochemical and histological changes in liver. Punjab Univ J Zool 8:1–13.
Allen EM, Florang VR, Davenport LL, . 2013. Cellular localization of dieldrin and structure-activity relationship of dieldrin analogues in dopaminergic cells. Chem Res Toxicol 26(7):1043–1054. 10.1021/tx300458b.23763672
Anderson RL, DeFoe DL. 1980. Toxicity and bioaccumulation of endrin and methoxychlor in aquatic invertebrates and fish. Environ Pollut 22(2):111–121.
ASTER. 1995. Assessment Tools for the Evaluation of Risk (ASTER) ecotoxicity profile. U.S. Environmental Protection Agency.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 2019. Endrin. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Bagchi M, Hassoun EA, Stohs SJ. 1992a. Endrin-induced increases in hepatic lipid peroxidation, membrane microviscosity, and DNA damage in rats. Arch Environ Contam Toxicol 23:1–5.1637188
Bagchi D, Bhattacharya G, Stohs SJ. 1996. In vitro and in vivo induction of heat shock (stress) protein (Hsp) gene expression by selected pesticides. Toxicology 112(1):57–68.
Bagchi D, Bagchi M, Hassoun E, . 1992b. Endrin-induced urinary excretion of formaldehyde, acetaldehyde, malondialdehyde and acetone in rats. Toxicology 75:81–89.
Bagchi D, Bagchi M, Hassoun E, . 1992c. Effect of endrin on the hepatic distribution of iron and calcium in female Sprague-Dawley rats. J Biochem Toxicol 7(1):37–42.1588572
Bagchi M, Hassoun EA, Bagchi D, . 1993a. Production of reactive oxygen species by peritoneal macrophages and hepatic mitochondria and microsomes from endrin-treated rats. Free Radic Biol Med 14:149–155.8381102
Bagchi D, Hassoun EA, Bagchi M, . 1993b. Protective effects of antioxidants against endrin-induced hepatic lipid peroxidation, DNA damage, and excretion of urinary lipid metabolites. Free Radic Biol Med 15:217–222.8375695
Bagchi E, Hassoun E, Akubue P, . 1993c. Comparative effects of endrin on hepatic lipid peroxidation and DNA damage, and nitric oxide production by peritoneal macrophages from C57BW6J and DBA/2 mice. Comp Biochem Physiol 105C(3):525–529.
Bagchi D, Bagchi M, Hassoun EA, . 1995a. In vitro and in vivo generation of reactive oxygen species, DNA damage and lactate dehydrogenase leakage by selected pesticides. Toxicology 104(1–3):129–140.8560491
Bagchi M, Ghosh S, Bagchi D, . 1995b. Protective effects of lazaroid U74389F (16-desmethyl tirilazad) on endrin-induced lipid peroxidation and DNA damage in brain and liver and regional distribution of catalase activity in rat brain. Free Radic Biol Med 19(6):867–872.8582661
Bagchi D, Bagchi M, Tang L, . 1997. Comparative in vitro and in vivo protein kinase C activation by selected pesticides and transition metal salts. Toxicol Lett 91(1):31–37.9096284
Bagchi D, Balmoori J, Bagchi M, . 2000. Role of p53 tumor suppressor gene in the toxicity of TCDD, endrin, naphthalene, and chromium (VI) in liver and brain tissues of mice. Free Radic Biol Med 28(6):895–903.10802220
Bagchi D, Balmoori J, Bagchi M, . 2002. Comparative effects of TCDD, endrin, naphthalene and chromium (VI) on oxidative stress and tissue damage in the liver and brain tissues of mice. Toxicology 175(1–3):73–82.12049837
Baldwin MK, Hutson DH. 1980. Analysis of human urine for a metabolite of endrin by chemical oxidation and gas-liquid chromatography as an indicator of exposure to endrin. Analyst 105:60–65.7386890
Baldwin MK, Robinson J, Parke DV. 1970. Metabolism of endrin in the rat. J Agric Food Chem 18:1117–1123.5483050
Baldwin MK, Crayford JV, Hutson DH, . 1976. The metabolism and residues of [14C] endrin in lactating cows and laying hens. Pestic Sci 7:575–594.
Bapayeva G, Issayeva R, Zhumadilova A, . 2016. Organochlorine pesticides and female puberty in South Kazakhstan. Reprod Toxicol 65:67–75. 10.1016/j.reprotox.2016.06.017.27346842
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bartha R, Lanzilotta RP, Pramer D. 1967. Stability and effects of some pesticides in soil. Appl Microbiol 15:67–75.6031443
Bason CW, Colborn T. 1992. U.S. Application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. In: Mehlman MA, ed. Chemically-induced alterations in sexual and functional development: The wildlife/human connection. Vol. 21. Princeton, NJ: Princeton Scientific Publishing Co., 335–345.
Bedford CT, Hutson DH, Natoff IL. 1975a. The acute toxicity of endrin and its metabolites to rats. Toxicol Appl Pharmacol 33:115–121.1162700
Bedford CT, Harrod RK, Hoadley EC, . 1975b. The metabolic fate of endrin in the rabbit. Xenobiotica 5(8):485–500.809931
Bedi JS, Gill JP, Aulakh RS, . 2013. Pesticide residues in human breast milk: risk assessment for infants from Punjab, India. Sci Total Environ 463–464:720–726. 10.1016/j.scitotenv.2013.06.066.
Bidleman TF. 1981. Interlaboratory analysis of high molecular weight organochlorines in ambient air. Atmos Environ 15:619–624.
Bloomquist JR. 1992. Intrinsic lethality of chloride-channel-directed insecticides and convulsants in mammals. Toxicol Letters 60:289–298.
Blus LJ, Henny CJ, Grove RA. 1989. Rise and fall of endrin usage in Washington State fruit orchards: Effects on wildlife. Environ Pollut 60:331–349.15092385
Boada LD, Zumbado M, Henriquez-Hernandez LA, . 2012. Complex organochlorine pesticide mixtures as determinant factor for breast cancer risk: A population-based case-control study in the Canary Islands (Spain). Environ Health 11:28. 10.1186/1476-069x-11-28.22534004
Boada LD, Henriquez-Hernandez LA, Zumbado M, . 2016. Organochlorine pesticides exposure and bladder cancer: Evaluation from a gene-environment perspective in a hospital-based case-control study in the Canary Islands (Spain). J Agromedicine 21(1):34–42. 10.1080/1059924x.2015.1106374.26479327
Bordet F, Mallet J, Maurice L, . 1993. Organochlorine pesticide and PCB congener content of French human milk. Bull Environ Contam Toxicol 50:425–432.8428123
Budavari S. 1989. Endrin. In: Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11^th^ ed. Rahway, NJ: Merck & Co., Inc.,
Burton WB, Pollard GE. 1974. Rate of photochemical isomerization of endrin in sunlight. Bull Environ Contam Toxicol 12:113–116.4433846
Buttner JK, Makarewicz JC, Lewis TW. 1995. Concentration of selected priority organic contaminants in fish maintained on formulated diets in Lake Ontario waters. Prog Fish Cult 57:141–146.
Carbajal-Rodriguez L, Oldak-Skvirsky D, Loreda-Abdala A, . 1990. Intoxication por endrin. Bol Med Hosp Infant Mex 47(2):100–102.2337463
Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the United States. Environ Monit Assess 5:155–163.24257992
Carey AE, Wiersma GB, Tai H. 1976. Pesticide residues in urban soils from 14 United States cities, 1970. Pestic Monit J 10(2):54–60.1005060
Carey AE, Gowen JA, Tai H, . 1979. Pesticide residue levels in soils and crops from 37 states, 1972 National Soils Monitoring Program (IV). Pestic Monit J 12:209–229.461116
Carey AE, Yang HSC, Wiersma GB, . 1980. Residual concentrations of propanil, TCAB and other pesticides in rice-growing soils in the United States, 1972. Pestic Monit J 14:23–25.7422467
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume2_Mar2018.pdf. April 06, 2018.
CDC. 2019. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2018. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. April 06, 2018.
Chan CH, Bruce G, Harrison B. 1994. Wet deposition of organochlorine pesticides and polychlorinated biphenyls to the Great Lakes. J Great Lakes Res 20(3):546–560.
Chen MW, Santos HM, Que DE, . 2018. Association between organochlorine pesticide levels in breast milk and their effects on female reproduction in a Taiwanese population. Int J Environ Res Public Health 15(5):1–22. 10.3390/ijerph15050931.
Chernoff N, Kavlock RJ, Hanisch RC, . 1979. Perinatal toxicity of endrin in rodents. I. Fetotoxic effects of prenatal exposure in hamsters. Toxicology 13(2):155–165.516075
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coble Y, Hildebrandt P, Davis J, . 1967. Acute endrin poisoning. JAMA 202:489–493.6072317
Cocco P, Brennan P, Ibba A, . 2008. Plasma polychlorobiphenyl and organochlorine pesticide level and risk of major lymphoma subtypes. Occup Environ Med 65(2):132–140. 10.1136/oem.2007.033548.17699548
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Coleman RL, Lawrence CH, Sowell WL. 1968. Trace metal alterations following sub-acute exposure to endrin. Bull Environ Contam Toxicol 3(5):284–295. 10.1007/bf01623626.24185305
CSWRCB. 1986. Ground water contamination by toxic substances, California assessment. Sacramento, CA: California State Water Resources Control Board.
Curley A, Jennings RW, Mann HT, . 1970. Measurement of endrin following epidemics of poisoning. Bull Environ Contam Toxicol 5(1):24–29. 10.1007/bf01545119.24185719
Davies K. 1988. Concentrations and dietary intake of selected organochlorines, including PCBs, PCDDs and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17(2):263–276.
Davies GM, Lewis I. 1956. Outbreak of food poisoning from bread made of chemically contaminated flour. Br Med J 11:393–398.
De Bruijin J, Busser F, Seinen W, . 1989. Determination of octanol water partition coefficients for hydrophobic organic chemicals with the “slow-stirring” method. Environ Toxicol Chem 8:499–512.
De Peyster A, Donohoe R, Slymen DJ. 1993. Aquatic biomonitoring of reclaimed water for potable use: The San Diego health effects study. J Toxicol Environ Health 39:121–142.8492326
Deichmann WB, MacDonald WE, Blum E, . 1970. Tumorigenicity of aldrin, dieldrin and endrin in the albino rat. Ind Med 39:37–45.
Dewailly E, Ayotte P, Bruneau S, . 1993. Inuit exposure to organochlorines through the aquatic food chain in arctic Quebec. Environ Health Perspect 101:618–620.8143594
Dikshith TSS, Datta KK. 1973. Endrin induced cytological changes in albino rats. Bull Environ Contam Toxicol 9(2):65–69.4781359
Ditraglia D, Brown DP, Namekata T, . 1981. Mortality study of workers employed at organochlorine pesticide manufacturing plants. Scand J Work Environ Health 7:140–146.7330625
Djordjevic MV, Hofmann D, Fan J. 1994. Assessment of chlorinated pesticides and polychlorinated biphenyls in adipose breast tissue using a supercritical fluid extraction method. Carcinogenesis 15(11):2581–2585.7955109
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
Doherty FG, Evans DW, Neuhauser EF. 1993. An assessment of total and leachable contaminants in zebra mussels (Dreissena polymorpha) from Lake Erie. Ecotoxicol Environ Saf 25:328–340.7691526
Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5(6):541–544.
Eisenlord G, Loquvam GS, Leung S. 1968. Results of reproduction study of rats fed diets containing endrin over three generations. Hine Laboratories. Prepared for Shell Chemical Company and Velsicol Chemical Corporation.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
El Morsi DA, Rahman RH, Abou-Arab AA. 2012. Pesticides residues in Egyptian diabetic children: A preliminary study. J Clin Toxicol 02(06):1000138. 10.4172/2161-0495.1000138.
EPA. 1979a. Endrin; Intent to cancel registrations and denial of applications for registration of pesticide products containing endrin, and statement of reasons. U.S. Environmental Protection Agency. Fed Regist 44:43632–43657. https://www.loc.gov/item/fr044144/. August 20, 2020.
EPA. 1979b. Endrin: Position document 4. Washington, DC: U.S. Environmental Protection Agency. PB81109480. EPASPRD8039.
EPA. 1979c. Water-related environmental fate of 129 priority pollutants. Vol I: Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100K7FH.txt. August 20, 2020.
EPA. 1980. Ambient water quality criteria document for endrin. Cincinnati, OH: U.S. Environmental Protection Agency. EPA440580047. https://www.epa.gov/sites/production/files/2019-03/documents/ambient-wqc-endrin-1980.pdf. August 20, 2020.
EPA. 1981. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014.
EPA. 1982. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600482057. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000ATB1.txt. August 20, 2020.
EPA. 1984a. Written communication (August 29) to Velsicol Chemical Company, regarding notice of intent to cancel registration: Velsicol technical endrin (EPA Registration No. 876-20). Washington, DC: U.S. Environmental Protection Agency.
EPA. 1984b. Analytical reference standards and supplemental data: The pesticides and industrial chemicals repository. U.S. Environmental Protection Agency. EPA600484082. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000AU5I.txt. August 20, 2020.
EPA. 1985a. Written communication (July 29) to Velsicol Chemical Company, regarding final cancellation notice: Velsicol technical endrin (EPA Registration No. 876.20). Washington, DC: U.S. Environmental Protection Agency.
EPA. 1985b. Drinking water criteria document for endrin. Washington, DC: U.S. Environmental Protection Agency. EPA600X84176. https://cfpub.epa.gov/ncea/risk/era/recordisplay.cfm?deid=33710. August 20, 2020.
EPA. 1985c. Suspended, cancelled and restricted pesticides. Washington, DC: U.S. Environmental Protection Agency. EPA740K85001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91017N0P.txt. August 20, 2020.
EPA. 1987a. Land disposal restrictions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
EPA. 1987b. Land disposal restrictions for certain “California List” hazardous wastes and modifications to the framework. U.S. Environmental Protection Agency. Fed Regist 52:25760–25763, 25791. https://www.loc.gov/item/fr052130/. August 20, 2020.
EPA. 1988. Pesticides in ground water data base: 1988 interim report. Washington, DC: U.S. Environmental Protection Agency. EPA5400989036. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000O1PT.txt. August 20, 2020.
EPA. 1992a. National study of chemical residues in fish. Volume I. Washington, DC: U.S. Environmental Protection Agency. EPA823R92008A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20003VSF.txt. August 20, 2020.
EPA. 1992b. National primary drinking water regulations: Synthetic organic chemicals and inorganic chemicals. Final rule. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141 and 142.
EPA. 1993. Status of pesticides in reregistration and special review. Washington, DC: U.S. Environmental Protection Agency. EPA738R93009.
EPA. 1994. Estimation Programs Interface Suite™ for Microsoft® Windows. Henry’s law constant program (HENRYWIN). Washington, DC: U.S. Environmental Protection Agency.
EPA. 1995a. Estimation Programs Interface Suite™ for Microsoft® Windows. Octanol-Water Partition Coefficient Program (KOWWIN). Washington, DC: U.S. Environmental Protection Agency.
EPA. 1995b. Estimation Programs Interface Suite™ for Microsoft® Windows. Atmospheric oxidation program (AOPWIN). Washington, DC: U.S. Environmental Protection Agency.
EPA. 1995c. The national listing of fish consumption advisories and bans. Washington DC: U.S. Environmental Protection Agency. EPA823C95001.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
FASE. 1996. Pesticide exports from US ports, 1992-1994. Los Angeles, CA: Foundation for Advancements in Science and Education.
Fazzalari FA. 1978. ASTM/DS-48A: Compilation of odor and taste threshold values. Philadelphia, PA: American Society for Testing and Materials. 58.
FDA. 1988. Residues in foods - 1987. U.S. Food and Drug Administration. J AOAC Int 71(6):156A–174A.
FDA. 1989. Residues in foods - 1988. U.S. Food and Drug Administration. J Assoc Off Anal Chem 72(5):133A–152A.
FDA. 1990. Residues in foods - 1989. U.S. Food and Drug Administration. J AOAC Int 73(5):127A–146A.
FDA. 1991. Residues in foods - 1990. U.S. Food and Drug Administration. J AOAC Int 74(5):121A–140A.
FDA. 1992. Residue monitoring 1991. U.S. Food and Drug Administration J AOAC Int 75(5):135A–157A.
FDA. 1993. Residue monitoring 1992. U.S. Food and Drug Administration J AOAC Int 76(5):127A–147A.
FDA. 1994. Residue monitoring 1993. U.S. Food and Drug Administration. J AOAC Int 77(5):163A–185A. 10.1093/jaoac/77.5.161A.
FDA. 1995. Residue monitoring 1994. U.S. Food and Drug Administration. J AOAC Int 78(5):119A–142A.
FDA. 2006. Total diet study - Market Baskets 1991-3 through 2003-4. U.S. Food and Drug Administration. https://www.fda.gov/media/77962/download. August 19, 2020.
FDA. 2017a. Pesticide residue monitoring 2017 report and data. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-2017-report-and-data. August 19, 2020.
FDA. 2017b. Analytical results of the total diet study. U.S. Food and Drug Administration. https://www.fda.gov/food/total-diet-study/analytical-results-total-diet-study. August 11, 2020.
FDA. 2017c. Subpart B - Requirements for specific standardized beverages. Bottled water. Code of Federal Regulations. Washington, DC: U.S. Food and Drug Administration. Vol. 21 CFR 165.110, https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Fernandez MF, Olmos B, Granada A, . 2007. Human exposure to endocrine-disrupting chemicals and prenatal risk factors for cryptorchidism and hypospadias: A nested case-control study. Environ Health Perspect 115(Suppl 1):8–14. 10.1289/ehp.9351.18174944
Ford WM, Hill EP. 1991. Organochlorine pesticides in soil sediments and aquatic animals in the Upper Steele Bayou watershed of Mississippi. Arch Environ Contam Toxicol 20:161–167.
Foster GD, Gates PM, Foreman WT. 1993. Determination of dissolved-phase pesticides in surface water from the Yakima River Basin, Washington, using the Goulden large-sample extractor and gas chromatography/mass spectrometry. Environ Sci Technol 27(9):1911–1917.
Freire C, Lopez-Espinosa MJ, Fernandez M, . 2011. Prenatal exposure to organochlorine pesticides and TSH status in newborns from Southern Spain. Sci Total Environ 409(18):3281–3287. 10.1016/j.scitotenv.2011.05.037.21683986
Freire C, Koifman RJ, Sarcinelli P, . 2012. Long term exposure to organochlorine pesticides and thyroid function in children from Cidade dos Meninos, Rio de Janeiro, Brazil. Environ Res 117:68–74. 10.1016/j.envres.2012.06.009.22776325
Freire C, Koifman RJ, Sarcinelli PN, . 2013. Long-term exposure to organochlorine pesticides and thyroid status in adults in a heavily contaminated area in Brazil. Environ Res 127:7–15. 10.1016/j.envres.2013.09.001.24183346
Freire C, Koifman RJ, Sarcinelli PN, . 2014. Association between serum levels of organochlorine pesticides and sex hormones in adults living in a heavily contaminated area in Brazil. Int J Hyg Environ Health 217(2–3):370–378. 10.1016/j.ijheh.2013.07.012.23972672
Fujii Y, Ito Y, Harada KH, . 2012. Comparative survey of levels of chlorinated cyclodiene pesticides in breast milk from some cities of China, Korea and Japan. Chemosphere 89(4):452–457. 10.1016/j.chemosphere.2012.05.098.22743181
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14:515–534.5787520
Gartrell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J AOAC Int 69:146–161.
Genuis SJ, Lane K, Birkholz D. 2016. Human elimination of organochlorine pesticides: Blood, urine, and sweat study. BioMed Res Int 2016:1624643. 10.1155/2016/1624643.27800487
Ghadiri H, Rose CW, Connell DW. 1995. Degradation of organochlorine pesticides in soils under controlled environment and outdoor conditions. J Environ Manage 43:141–151.
Giesy JP, Verbrugge DA, Othout RA, . 1994. Contaminants in fishes from Great Lakes-influenced sections and above dams of three Michigan rivers. I: Concentrations of organochlorine insecticides, polychlorinated biphenyls, dioxin equivalents, and mercury. Arch Environ Contam Toxicol 27:202–212.8060164
Gladen BC, Monaghan SC, Lukyanova EM, . 1999. Organochlorines in breast milk from two cities in Ukraine. Environ Health Perspect 107(6):459–462.10339445
Glatt H, Jung R, Oesch F. 1983. Bacterial mutagenicity investigation of epoxides: Drugs, drug metabolites, steroids and pesticides. Mutat Res 11:99–118.
Goldenthal EI. 1978a. Endrin: Teratology study in rats. International Research and Development Corporation. Prepared for Velsicol Chemical Corporation.
Goldenthal EI. 1978b. Endrin: Teratology study in hamsters. International Research and Development Corporation. Prepared for Velsicol Chemical Corporation.
Good EE, Ware GW. 1969. Effects of insecticides on reproduction in the laboratory mouse: IV. Endrin and dieldrin. Toxicol Appl Pharmacol 14:201–203.5813270
Gowda TK, Sethunathan N. 1976. Persistence of endrin in Indian rice soils under flooded conditions. J Agric Food Chem 24:750–753.956537
Gray LE, Kavlock RJ, Chernoff N, . 1981. Perinatal toxicity of endrin in rodents. III. Alterations of behavioral ontogeny. Toxicology 21(3):187–202.7292507
Guillette EA, Meza MM, Aquilar MG, . 1998. An anthropological approach to the evaluation of preschool children exposed to pesticides in Mexico. Environ Health Perspect 106(6):347–353.9618351
Gunderson EL. 1988. Chemical contaminants monitoring: FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 71(6):1200–1209.
Hansen DJSSC, Forester J. 1977. Endrin: Effects on the entire life-cycle of saltwater fish, Cyprinbdon variegatus. J Toxicol Environ Health 3:721–733.592434
Harkov R. 1986. Semivolatile organic compounds in the atmosphere: A review. J Environ Sci 21(5):409–433.
Hassan MQ, Numan IT, Al-Nasiri N, . 1991. Endrin-induced histopathological changes and lipid peroxidation in livers and kidneys of rats, mice, guinea pigs and hamsters. Toxicol Pathol 19(2):108–114.1771364
Hassoun EA, Stohs SJ. 1996a. Comparative teratological studies on TCDD, endrin and lindane in C57BL/6J and DBA/2J mice. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 113(3):393–398.8697196
Hassoun EA, Stohs SJ. 1996b. TCDD, endrin and lindane induced oxidative stress in fetal and placental tissues of C57BL/6J and DBA/2J mice. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 115(1):11–18.8983165
Hassoun EA, Bagchi D, Stohs SJ. 1996. TCDD endrin and lindane induced increases in lipid metabolites in maternal sera and amniotic fluids of pregnant C57BL/6J and DBA/2J mice. Res Commun Mol Pathol Pharmacol 94(2):157–169.8987113
Hassoun E, Bagchi M, Bagchi D, . 1993. Comparative studies on lipid peroxidation and DNA-single strand breaks induced by lindane, DDT, chlordane and endrin in rats. Comp Biochem Physiol 104C(3):427–431.
Hellou J, Warren WG, Payne JF. 1993. Organochlorines including polychlorinated biphenyls in muscle, liver, and ovaries of cod, Gadus morhua. Arch Environ Contam Toxicol 25:497–505.8239716
Henríquez-Hernández LA, Luzardo OP, Zumbado M, . 2014. Blood pressure in relation to contamination by polychlorobiphenyls and organochlorine pesticides: Results from a population-based study in the Canary Islands (Spain). Environ Res 135:48–54. 10.1016/j.envres.2014.05.036.25262074
Henríquez-Hernández LA, Luzardo OP, Valerón PF, . 2017. Persistent organic pollutants and risk of diabetes and obesity on healthy adults: Results from a cross-sectional study in Spain. Sci Total Environ 607–608:1096–1102. 10.1016/j.scitotenv.2017.07.075.
Hermanutz R. 1978. Endrin and malathion toxicity to flagfish (Jordanella floridae). Arch Environ Contam Toxicol 7:159–168.677942
Hermanutz RO, Eaton JG, Mueller LH. 1985. Toxicity of endrin and malathion mixtures to flagfish (Jordanella floridae). Arch Environ Contam Toxicol 14:307–314.4004338
Hernandez JP, Mota LC, Baldwin WS. 2009. Activation of CAR and PXR by dietary, environmental and occupational chemicals alters drug metabolism, intermediary metabolism, and cell proliferation. Curr Pharmacogenomics Person Med 7(2):81–105.20871735
Hoogendam I, Versteeg JPJ, DeVlieger M. 1962. Electroencephalograms in insecticide toxicity. Arch Environ Health 4:92–100.
Hoogendam I, Versteeg JPJ, DeVlieger M. 1965. Nine years’ toxicity control in insecticide plants. Arch Environ Health 10:441–448.14247341
Howard PH. 1991. Endrin. In: Handbook of environmental fate and exposure data for organic chemicals. Vol. 3. Chelsea, MI: Lewis Publishers, 349–361.
Hundley HK, Cairns T, Luke MA, . 1988. Pesticide residue findings by the Luke method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J AOAC Int 71(5):875–892.
Hunter J, Maxwell JD, Stewart DA, . 1972. Increased hepatic microsomal enzyme activity from occupational exposure to certain organochlorine pesticides. Nature 237:399–401.4557326
Hutson DH. 1981. The metabolism of insecticides in man. Prog Pestic Biochem 1:247–285.
Hutson DH, Baldwin MK, Hoadley EC. 1975. Detoxication and bioactivation of endrin in the rat. Xenobiotica 5(11):697–714.1189464
IARC. 1974. IARC Monographs on the evaluation of carcinogenic risk of chemicals to man: Some organochlorine pesticides Lyon, France: International Agency for Research on Cancer. Vol. 5, https://publications.iarc.fr/_publications/media/download/1553/09c5dcf270093e55563e337ebb705f9b21ea2feb.pdf. August 20, 2020.
IARC. 1987. Endrin. In: IARC Monographs on the evaluation of carcinogenic risks to humans. Supplement 7. Overall evaluations of carcinogenicity: An updating of IARC Monographs Volumes 1 to 42. Lyon, France: International Agency for Research on Cancer, 63. http://monographs.iarc.fr/ENG/Monographs/suppl7/Suppl7.pdf. November 15, 2017.
IDNR. 1987. Pesticides in water samples using surface water sources. Des Moines, IA: Iowa Department of Natural Resources. PB88136916. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88136916.xhtml. August 20, 2020.
IRIS. 2002. Endrin. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0363_summary.pdf. November 15, 2017.
IRPTC. 1985. Treatment and disposal methods for waste chemicals. Geneva, Switzerland: International Register of Potentially Toxic Chemicals.
Jacobnizer H, Raybin HW. 1959. Briefs on accidental chemical poisonings in New York City. Poisoning by insecticide (Endrin). N Y State J Med 59:2017–2022.13644660
Janik F, Wolf HU. 1992. The Ca^2+^-transport-ATPase of human erythrocytes as an in vitro toxicity test system - Acute effects of some chlorinated compounds. J Appl Toxicol 12:351–358.1447481
Jaquess AB, Winterlin W, Peterson D. 1989. Feasibility of toxaphene transport through sandy soil. Bull Environ Contam Toxicol 42:417–423.2706352
Jarvinen AW, Tyo RM. 1978. Toxicity to fathead minnows of endrin in food and water. Arch Environ Contam Toxicol 7:409–421.755443
Kan-Do Office. 1995. Accumulated pesticides and industrial chemical findings from a ten-year study of ready-to-eat foods. J AOAC Int 78(3):614–630.7756874
Kavlock RJ, Chernoff N, Rogers EH. 1985. The effect of acute maternal toxicity on fetal development in the mouse. Teratog Carcinog Mutagen 5:1–15.
Kavlock RJ, Chernoff N, Hanisch RC, . 1981. Perinatal toxicity of endrin in rodents. II. Fetotoxic effects of prenatal exposure in rats and mice. Toxicology 21(2):141–150.7281202
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Kennicutt MC, Wade BJ, Presley AG, . 1994. Sediment contaminants in Casco Bay, Maine: Inventories, sources, and potential for biological impact. Environ Sci Technol 28(1):1–15.22175827
Keplinger ML, Deichmann WB. 1967. Acute toxicity of combinations of pesticides. Toxicol Appl Pharmacol 10:586–595.6059673
Kettering. 1969. Effects exerted upon beagle dogs during a period of two years by the introduction of 1,2,3,4,10,10-hexachloro-6,7- epoxy-1,4,4a,5,6,7,8,8a-octahydro-1,4-endo, endo-5,8-dimethanonaphthalene into their daily diets. Cincinnati, OH: Kettering Laboratory. Report to Velsicol Chemical Corporation.
Kettering. 1971. The reproductive capacity among dogs fed diets containing endrin. The Kettering Laboratory, University of Cincinnati. Prepared for Velsicol Chemical Corporation.
Khan MA, Jovanovich LV, Martin LT, . 1998. Effects of photoisomers of cyclodiene insecticides on liver and microsomal cytochrome P450 in rats. Arch Toxicol 72(2):74–83.9456078
Kintz P, Baron L, Tracqui A, . 1992. A high endrin concentration in a fatal case. Forensic Sci Int 54(2):177–180.1639284
Klevay LM. 1971. Endrin excretion by the isolated perfused rat liver: A sexual difference. Cincinnati, OH: University of Cincinnati.
Knoevenagel K, Himmelreich R. 1976. Degradation of compounds containing carbon atoms by photooxidation in the presence of water. Arch Environ Contam Toxicol 4:324–333.970984
Kodavanti PRS, Mehrotra BD, Chetty SC, . 1988. Effect of selected insecticides on rat brain synaptosomal adenylate cyclase and phospodiesterase. J Toxicol Environ Health 25:207–215.2845111
Korte F, Klein W, Weisgerber A, . 1970. Recent results in studies on the fate of chlorinated insecticides. In: Inter-American conference on toxic and occupational medicine: 6th Pesticides symposia. Coral Gables, FL: University of Miami, 51–56.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kutz FW, Yobs AR, Yang HSC. 1976. National pesticide monitoring programs. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, Inc., 95–136.
Lawrence CH, Coleman RL, Sowell WL. 1968. Endrin induced trace metal alterations following acute exposure. Bull Environ Contam Toxicol 3(4):229–239. 10.1007/bf01684320.24185207
Leblanc GA. 1995. Trophic-level differences in the bioconcentration of chemicals: Implications in assessing environmental biomagnification. Environ Sci Technol 29:154–160.22200214
Lee RF. 1977. Fate of petroleum components in estuarine waters of the southeastern United States. In: Proceedings of 1977 Oil Spill Conference: Prevention, behavior, control, cleanup, March 8-10, 1977. Washington, DC: American Petroleum Institute, 611–616.
Lee TP, Moscati R, Park BH. 1979. Effects of pesticides on human leukocyte functions. Res Commun Chem Pathol Pharmacol 23(3):597–609.461978
Lemaire G, de Sousa G, Rahmani R. 2004. A PXR reporter gene assay in a stable cell culture system: CYP3A4 and CYP2B6 induction by pesticides. Biochem Pharmacol 68:2347–2358.15548381
Lemaire G, Mnif W, Mauvais P, . 2006. Activation of α- and β-estrogen receptors by persistent pesticides in reporter cell lines. Life Sci 79(12):1160–1169. 10.1016/j.lfs.2006.03.023.16626760
Lewis RG, Lee RE. 1976. Air pollution from pesticides: Sources, occurrences and dispersions. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Boca Raton, FL: CRC Press, 5–51.
Ligocki MP, Pankow JF. 1985. Assessment of adsorption/solvent extraction with polyurethane foam and adsorption/thermal desorption with Tenax-GC for the collection and analysis of ambient organic vapors. Anal Chem 57:1138–1144.
Lopez-Espinosa MJ, Granada A, Carreno J, . 2007. Organochlorine pesticides in placentas from Southern Spain and some related factors. Placenta 28(7):631–638. 10.1016/j.placenta.2006.09.009.17109956
Ludke JL. 1976. Organochlorine pesticide residues associated with mortality: Additivity of chlordane and endrin. Bull Environ Contam Toxicol 16:253–260.974274
Lyman WJ. 1990. Handbook of chemical property estimation methods. Washington, DC: American Chemical Society. 4-1 to 4-9.
Marsh JM. 1993. Assessment of nonpoint source pollution in stormwater runoff in Louisville, (Jefferson County) Kentucky, USA. Arch Environ Contam Toxicol 25:446–455.
Maslansky CJ, Williams GM. 1981. Evidence for an epigenetic mode of action in organochlorine pesticide hepatocarcinogenicity: A lack of genotoxicity in rat, mouse, and hamster hepatocytes. J Toxicol Environ Health 8:121–130.7328699
Mason JW, Rowe DR. 1976. The accumulation and loss of dieldrin and endrin in the eastern oyster. Arch Environ Contam Toxicol 4:349–360.9913
Mathews TD. 1994. Contaminants in recreationally important estuarine finfish from South Carolina. Bull Environ Contam Toxicol 53:412–419.7919719
Maule A, Plyte S, Quirk V. 1987. Dehalogenation of organochlorine insecticides by mixed anaerobic microbial populations. Pestic Biochem Physiol 27:229–236.
McGregor DB, Brown AG, Howgate S, . 1991. Responses of the L5178Y mouse lymphoma cell forward mutation assay V: 27 Coded chemicals. Environ Mol Mutagen 17:196–219.1902415
Mehrotra BD, Moorthy KS, Ravichandra R, . 1989. Effects of cyclodiene compounds on calcium pump activity in rat brain and heart. Toxicology 54:17–29.2536969
Mersch-Sundermann V, Schneider U, Klopman G, . 1994. SOS induction in Escherichia coli and Salmonella mutagenicity: A comparison using 330 compounds. Mutagenesis 9(3):205–224.7934961
Metcalf RL, Kapoor IP, Lu PY, . 1973. Model ecosystem studies of the environmental fate of six organochlorine pesticides. Environ Health Perspect 4:35–44.4124493
Miller MA. 1993. Maternal transfer of organochlorine compounds in salmonines to their eggs. Can J Fish Aquat Sci 50(7):1405–1413. 10.1139/f93-161.
Miller PE, Fink GB. 1973. Brain serotonin level and pentylenetetrazol seizure threshold in dieldrin and endrin treated mice. Proc West Pharmacol Soc 16:195–197.
Minyard JP, Roberts WE. 1991. State findings on pesticide residues in foods - 1988 and 1989. J AOAC Int 74:438–452.
Moriya F, Hashimoto Y. 1999. Comparative studies on tissue distributions of organophosphorus, carbamate and organochlorine pesticides in decedents intoxicated with these chemicals. J Forensic Sci 44(6):1131–1135.10582355
Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
Mount DI, Putnicki GJ. 1966. Summary report of 1963 Mississippi fish kill. In: Trefethen JB, ed. Transactions of the thirty-first North American wildlife and natural resources conference. Washington, DC: Wildlife Management Institute, 177–184.
Mumtaz MM, Tully DB, El-Masri HA, . 2002. Gene induction studies and toxicity of chemical mixtures. Environ Health Perspect 110(Suppl 6):947–956.
Murray HE, Beck JN. 1990. Concentrations of selected chlorinated pesticides in shrimp collected from the Calcasieu River/Lake complex, Louisiana. Bull Environ Contam Toxicol 44:798–804.2111719
Narahashi T. 1991. Transmitter-activated ion channels as the target of chemical agents. Adv Exp Med Biol 287:61–72.1722072
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35.
Nash RG. 1983. Comparative volatilization and dissipation rates of several pesticides from soil. J Agric Food Chem 31:210–217.
Nash RG, Woolson EA. 1967. Persistence of chlorinated hydrocarbon insecticides in soils. Science 157:924–927.17792829
Nash RG, Harris WG. 1973. Chlorinated hydrocarbon insecticide residues in crops and soil. J Environ Qual 2:267–273.
Nash RG, Beall M, Harris WG. 1972. Endrin transformations in soil. J Environ Qual 1(4):391–394.
NCI. 1979. Bioassay of technical-grade endrin for possible carcinogenicity. Bethesda, MD: National Cancer Institute. Technical Report Series No. 12. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr012.pdf. October 29, 2020.
NIOSH. 1994. Endrin. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/72208.html. November 15, 2017.
NIOSH. 2016. Endrin. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0252.html. November 15, 2017.
NLM. 2020. Pubchem data: Endrin. https://pubchem.ncbi.nlm.nih.gov/compound/12358480. September 9, 2020.
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
Numan IT, Hassan MQ, Stohs SJ. 1990a. Endrin-induced depletion of glutathione and inhibition of glutathione peroxidase activity in rats. Gen Pharmacol 21(5):625–628.2276583
Numan IT, Hassan MQ, Stohs SJ. 1990b. Protective effects of antioxidants against endrin-induced lipid peroxidation, glutathione depletion, and lethality in rats. Arch Environ Contam Toxicol 19:302–306.2353831
NWQMC. 2020. Water Quality Portal data: Endrin. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=Endrin&mimeType=csv. August 19, 2020.
Osaba L, Aguirre A, Alonso A, . 1999. Genotoxicity testing of six insecticides in two crosses of the Drosophila wing spot test. Mutat Res 439(1):49–61.10029675
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Ottevanger CF, Van Sittert NJ. 1979. Relation between anti-12-hydroxy-endrin excretion and enzyme induction in workers involved in the manufacture of endrin. In: Strik JJ, Koeman JH, eds. Chemical porphyria in man. Amsterdam, Netherlands: Elsevier/North-Holland Biomedical Press, 123–129.
Ottolenghi AD, Haseman JK, Suggs F. 1974. Teratogenic effects of aldrin, dieldrin, and endrin in hamsters and mice. Teratology 9:11–16.4204659
Pandey BB. 1978. A note on endrin poisoning in bullocks. Indian Vet J 55:253.
Parkinson RW, Wang TC, White JR, . 1993. Distribution and migration of pesticide residues in mosquito control impoundments St. Lucie County, Florida, USA. Environ Geol 22:26–32.
Patil KC, Matsumura F, Boush GM. 1970. Degradation of endrin, aldrin, and DDT by soil microorganisms. Appl Microbiol 19:879–881.4192889
Patil KC, Matsumura F, Boush GM. 1972. Metabolic transformation of DDT, dieldrin, aldrin, and endrin by marine microorganisms. Environ Sci Technol 6:629–632.
Petrella VJ, McKinney JD, Fox JP, . 1977. Identification of metabolites of endrin. Metabolism in endrin susceptible and resistant strains of pine mice. J Agric Food Chem 25(2):393–398.838980
Petty JD, Huckins JN, Martin DB. 1995. Use of semipermeable membrane devices (SPMDS) to determine bioavailable organochlorine pesticide residues in streams receiving irrigation drainwater. Chemosphere 30(10):1891–1903.
Phillips DD, Pollard GE, Soloway SB. 1962. Thermal isomerization of endrin and its behavior in gas chromatography. J Agric Food Chem 10(3):217–221.
Pi N, Chia SE, Ong CN, . 2016. Associations of serum organohalogen levels and prostate cancer risk: Results from a case-control study in Singapore. Chemosphere 144:1505–1512. 10.1016/j.chemosphere.2015.10.020.26498098
Piccoli C, Cremonese C, Koifman RJ, . 2016. Pesticide exposure and thyroid function in an agricultural population in Brazil. Environ Res 151:389–398. 10.1016/j.envres.2016.08.011.27540871
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. GWMR 7:94–100.
Pohl HR, Tylenda CA. 2000. Breast-feeding exposure of infants to selected pesticides: A public health viewpoint. Toxicol Ind Health 16(2):65–77. 10.1177/074823370001600203.10798624
Polanco Rodriguez AG, Inmaculada Riba Lopez M, Angel DelValls Casillas T, . 2017. Levels of persistent organic pollutants in breast milk of Maya women in Yucatan, Mexico. Environ Monit Assess 89(2):59–64. 10.1007/s10661-017-5768-y.
Pontecorvo G, Fantaccione S. 2006. Recombinogenic activity of 10 chemical compounds in male germ cells of Drosophila melanogaster. Ecotoxicol Environ Saf 65(1):93–101. 10.1016/j.ecoenv.2005.05.022.16043220
Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
Quick MP, Shaw IC, Manser PA. 1989. A surprising case of endrin poisoning in dogs. J Forensic Sci Soc 29(5):331–338.2584949
Ressang AA, Titus I, Andar RS, . 1959. Aldrin, dieldrin and endrin intoxication in cats. Commun Vet 2:71–88.
Reuber MD. 1979. Carcinogenicity of endrin. Sci Total Environ 12:101–135.
Ribbens PH. 1985. Mortality study of industrial workers exposed to aldrin, dieldrin and endrin. Int Arch Occup Environ Health 56:75–79.4055072
Richardson A, Robinson J, Baldwin MK. 1970. Metabolism of endrin in the rat. Chem Ind 15:502–503.5440832
Richardson LA, Lane JR, Gardner WS, . 1967. Relationship of dietary intake to concentration of dieldrin and endrin in dogs. Bull Environ Contam Toxicol 2(4):207–219.24189782
Romero ML, Dorea JG, Granja AC. 2000. Concentrations of organochlorine pesticides in milk of Nicaraguan mothers. Arch Environ Health 55(4):274–278. 10.1080/00039890009603418.11005433
Rowley DL, Rab MA, Hardjotanojo W, . 1987. Convulsions caused by endrin poisoning in Pakistan. Pediatrics 79:928–934.3588147
Roy RR, Albert RH, Wilson P, . 1995. U.S. Food and Drug Administration Pesticide Program: Incidence level monitoring of domestic and imported pears and tomatoes. J AOAC Int 78(4):930–940.7580331
Runhaar EA, Sangster B, Greve PA, . 1985. A case of fatal endrin poisoning. Hum Toxicol 4:241–247.4007887
Samra NM, Selim AA. 2009. Organochlorine pesticides concentrations in maternal serum and their effects on umbilical cord serum pesticides concentrations, neonatal birth weight and gestational age. Aust J Basic Appl Sci 3:1972–1983.
Schaalan MF, Abdelraouf SM, Mohamed WA, . 2012. Correlation between maternal milk and infant serum levels of chlorinated pesticides (CP) and the impact of elevated CP on bleeding tendency and immune status in some infants in Egypt. J Immunotoxicol 9(1):15–24. 10.3109/1547691x.2011.606432.21962179
Schafer ML, Peeler JT, Gardner WS, . 1969. Pesticides in drinking water: Waters from the Mississippi and Missouri Rivers. Environ Sci Technol 3:1261–1269.
Schattenberg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J AOAC Int 75(5):925–933.
Schmitt CJ, Zajicek JL, Ribick MA. 1985. National pesticide monitoring program: Residues of organochlorine chemicals in freshwater fish, 1980-81. Arch Environ Contam Toxicol 14:225–260.3920980
Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in U.S. freshwater fish, 1976-1984. Arch Environ Contam Toxicol 19:748–781.21318506
Sharom MS, Miles JR, Harris CR, . 1980a. Behavior of 12 insecticides in soil and aqueous suspensions of soil and sediment. Water Res 14:1095–1100.
Sharom MS, Miles JR, Harris CR, . 1980b. Persistence of 12 insecticides in water. Water Res 14:1089–1093.
Sittig M. 1980. Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 366–373.
Smith-Baker C, Saleh MA. 2011. Hair as a marker for pesticides exposure. J Environ Sci 46(7):648–653. 10.1080/03601234.2012.597701.
Sobti RC, Krishan A, Davies J. 1983. Cytokinetic and cytogenetic effect of agricultural chemicals on human lymphoid cells in vitro. II. Organochlorine pesticides. Arch Toxicol 52:221–231.6860144
Speck LB, Maaske CA. 1958. The effects of chronic and acute exposure of rats to endrin. AMA Arch Ind Health 18:268–272.13570717
Spicer PE, Kereu RK. 1993. Organochlorine insecticide residues in human breast milk: A survey of lactating mothers from a remote area in Papua, New Guinea. Bull Environ Contam Toxicol 50:540–546.8467139
SRI. 1987. Endrin. In: Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 847.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Storm DL. 1994. Chemical monitoring of California’s public drinking water sources: Public exposures and health impacts. In: Wang RGM, ed. Water contamination and health. New York, NY: Marcel Dekker, Inc., 67–124.
Strachan WMJ. 1988. Toxic contaminants in rainfall in Canada: 1984. Environ Toxicol Chem 7:871–877.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. Journal (Water Pollution Control Federation) 53(1):1503–1518.
Takeuchi S, Matsuda T, Kobayashi S, . 2006. In vitro screening of 200 pesticides for agonistic activity via mouse peroxisome proliferator-activated receptor (PPAR)α and PPARγ and quantitative analysis of in vivo induction pathway. Toxicol Appl Pharmacol 217:235–244.17084873
Teshke K, Kelly SJ, Wiens M, . 1993. Concentrations of organochlorine pesticides in the adipose tissue of British Columbia. Can J Public Health 84(3):192–196.8358696
Tewari SN, Sharma IC. 1978. Study of the distribution of chlorinated organic pesticides in different autopsy materials of human poisoning cases using TLC and UV spectrophotometric techniques. Chemical Era 14:215–218.
Thomas RG. 1982. Volatilization from water. In: Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15-11 to 15-34.
Thomas RG. 1990. Volatilization from water. In: Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15-11 to 15-17.
Treon JF, Cleveland FP, Cappel J. 1955. Toxicity of endrin for laboratory animals. J Agric Food Chem 3:842–848.
Trotter WJ, Dickerson R. 1993. Pesticide residues in composited milk collected through the U.S. Pasteurized Milk Network. J AOAC Int 76(7):1220–1225.8286959
Tully DB, Cox VT, Mumtaz MM, . 2000. Six high-priority organochlorine pesticides, either singly or in combination, are nonestrogenic in transfected HeLa cells. Reprod Toxicol 14(2):95–102.10825672
Tyler-Schroeder DB. 1979. Use of the grass shrimp (Palaemonetes pugio) in a life-cycle toxicity test. In: Marking LL, Kimerle RA, eds. Aquatic toxicology. American Society for Testing and Materials, 159–170.
USDA. 1993. National Agricultural Pesticide Impact Assessment Program (NAPIAP). U.S. Department of Agriculture. Reregistration Notification Network (RNN) 3(11):1-1, 1-4.
Veith GD, Kosian P. 1983. Estimating bioconcentration potential from octanol/water partition coefficients. In: Mackay D, Paterson S, Eisenreich SJ, ., eds. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Publishers, 269–282.
Veith GD, Defoe DL, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. Environ Sci Technol 16(5):1040–1048.
Venkat JA, Shami S, Davis K, . 1995. Relative genotoxic activities of pesticides evaluated by a modified SOS microplate assay. Environ Mol Mutagen 25(1):67–76.7875128
Verschueren K. 1983. Endrin. In: Handbook of environmental data on organic chemicals 2^nd^ ed. New York, NY: Van Nostrand Reinhold Company, 606–611.
Versteeg JP, Jager KW. 1973. Long-term occupational exposure to the insecticides aldrin, dieldrin, endrin, and telodrin. Br J Ind Med 30:201–202.4703092
Vrij-Standhardt WC, Strik JJ, Ottevanger CF. 1979. Urinary D-glucaric acid and urinary total porphyrin excretion in workers exposed to endrin. In: Strik JJ, Koeman JH, eds. Chemical porphyria in man. Amsterdam, Netherlands: Elsevier/North Holland Biomedical Press, 113–121.
Wafford KA, Sattelle DB, Gant DB, . 1989. Noncompetitive inhibition of GABA receptors in insect and vertebrate CNS by endrin and lindane. Pestic Biochem Physiol 33:213–219.
Waller K, Prendergast TJ, Slagle A, . 1992. Seizures after eating a snack food contaminated with the pesticide endrin: The tale of the toxic taquitos. West J Med 157(6):648–651.1475948
Ward EM, Schulte P, Grajewski B, . 2000. Serum organochlorine levels and breast cancer: a nested case-control study of Norwegian women. Cancer Epidemiol Biomarkers Prev 9(12):1357–1367.11142422
Webb RE, Hartgrove RW, Randolph WC, . 1973. Toxicity studies in endrin-susceptible and resistant strains of pine mice. Toxicol Appl Pharmacol 25(1):42–47.4714338
Weeks DE. 1967. Endrin food-poisoning: A report on four outbreaks caused by two separate shipments of endrin-contaminated flour. Bull WHO 37:499–512.5301732
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Williams GM. 1980. Classification of genotoxic and epigenetic hepatocarcinogens using liver culture assays. Ann NY Acad Sci 349:273–282.6939363
Williams DT, LeBel GL, Junkins E. 1984. A comparison of organochlorine residues in human adipose tissue autopsy samples from two Ontario municipalities. J Toxicol Environ Health 13:19–29.6716511
Williams DT, LeBel GL, Junkins E. 1988. Organohalogen residues in human adipose autopsy samples from six Ontario municipalities. J AOAC Int 71(2):410–414.
Wolfe HR, Durham WF, Armstrong JF. 1963. Health hazards of the pesticides endrin and dieldrin: Hazards in some agricultural uses in the Pacific Northwest. Arch Environ Health 6:458–464.14001561
Worthing CR, Walker SB. 1983. Endrin. In: The Pesticide manual. 7^th^ ed. Hampshire, UK: British Crop Protection Council, 235.
Yess NJ, Gunderson EL, Roy RR. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J AOAC Int 76(3):492–507.8318840
Young RA, Mehendale HM. 1986. Effect of endrin and endrin derivatives on hepatobiliary function and carbon tetrachloride-induced hepatotoxicity in male and female rats. Food Chem Toxicol 24(8):863–868. 10.1016/0278-6915(86)90078-5.3781435
Zabik MJ, Schuetz RD, Burton WL, . 1971. Photochemistry of bioactive compounds: Studies of a major photolytic product of endrin. J Agric Food Chem 19:308–313.5546159
Zeiger E, Anderson B, Haworth S, . 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9:1–15.