# VERSION HISTORY

Date | Description
March 2021 | Final toxicological profile released
May 2019 | Draft for public comment toxicological profile released
August 1996 | Final toxicological profile released