# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding endrin in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for endrin.

Table 7-1 Regulations and Guidelines Applicable to Endrin

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2002
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 0.02 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.005 mg/L | EPA 2018a
EPA | DWEL | 0.01 mg/L | EPA 2018a
EPA | Lifetime health advisory | 0.002 mg/L | EPA 2018a
EPA | 10^−4^ Cancer risk | No data | EPA 2018a
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.002 mg/L | EPA 2009
EPA | PHG | 0.002 mg/L | EPA 2009
EPA | RfD | 3 ×10^−4^ mg/kg/day | IRIS 2002
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value | 0.0006 mg/L (0.6 µg/L) | WHO 2017
WHO | PTDI | 0.2 µg/kg body weight | WHO 2017
FDA | Substances Added to Food^a^ | No data | FDA 2020
FDA | Allowable level in bottled water | 0.002 mg/L | FDA 2017c
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | D^b^ | IRIS 2002
IARC | Carcinogenicity classification | Group 3^c^ | IARC 1987
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | 0.1 mg/m^3^ ^d^ | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | 0.1 mg/m^3^ ^d^ | NIOSH 2016
NIOSH | IDLH | 2 mg/m^3^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^e^ | 1.8 mg/m^3^ | DOE 2018a
DOE | PAC-2^e^ | 20 mg/m^3^ | DOE 2018a
DOE | PAC-3^e^ | 2,000 mg/m^3^ | DOE 2018a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group D: not classifiable as to human carcinogenicity.

c Group 3: not classifiable as to its carcinogenicity to humans.

d Skin designation.

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = Immediately Dangerous to Life or Health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; PHG = public health goal; PTDI = provisional tolerable daily intake; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization