# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of endrin, endrin aldehyde, and endrin ketone is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of endrin, endrin aldehyde, and endrin ketone is located in Table 4-2.

Table 4-1 Chemical Identity of Endrin, Endrin Aldehyde, and Endrin Ketone

Characteristic | Endrin | Endrin aldehyde | Endrin ketone | Reference
Chemical name | 2,7:3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a,2,2a,3,6,6a,7,7a-octahydro- (1aα,2β,2aβ,3α,6α,6aβ,7β,7aα)- | 1,2,4-Methenocyclopenta(cd)-entalene-5-carboxaldehyde, 2,2a,3,3,4,7-hexachlorodecahydro - (1α,2β,2aβ,4β,4aβ,5β, 6aβ,6bβ,7R*) | 2,5,7-Metheno-3H-cyclopenta(a)entalen-3-one,3b,4,5,6,6a-hexachlorodecahydro- (2α,3aβ,3bβ,4β,5β,6aβ, 7α,7aβ,8R*) | EPA 1984b
Synonym(s) | Endrin; 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4A,5,6,7,8,8A- octahydro-endo, endo-1,4:5,8-dimethanonaphthalene, and others | Endrin aldehyde; 1,2,4-methanecyclopenta(c,d)pentalene-5-carboxaldehyde, 2,2a,3,3,4,7-hexachlorodecahydro | Endrin ketone | NLM 2020
Registered trade name(s) | Mendrin, Hexacrin, Endrex experimental insecticide 269 | No data | Delta-keto 153 | NLM 2020; Sittig 1980
Chemical formula | C_12_H_8_Cl_6_O | C_12_H_8_Cl_6_O | C_12_H_8_Cl_6_O | EPA 1984b
Chemical structure | Formula | Formula | Formula | EPA 1984b
CAS registry | 72-20-8 | 7421-93-4 | 53494-70-5 | EPA 1984b

CAS = Chemical Abstracts Services

Table 4-2 Physical and Chemical Properties of Endrin, Endrin Aldehyde, and Endrin Ketone

Property | Endrin | Endrin aldehyde | Endrin ketone | Reference
Molecular weight | 380.9 | 381.9 | 380.9 | EPA 1984b
Color | White, colorless | No data | No data | IARC 1974; NLM 2020; Worthing and Walker 1983
Physical state | Crystalline solid | Solid | Solid | EPA 1984b; IARC 1974; NLM 2020
Melting point | 235°C; 226–230°C (decomposes) | 145–149°C; 235°C (decomposes) | No data | EPA 1981; NLM 2020; Worthing and Walker 1983
Boiling point | Decomposes at 246°C; decomposes above 200°C | No data | No data | ACGIH 1986; IARC 1974; NLM 2020
Density at 20°C | No data | No data | No data
Odor | 1.7 at 20°C | No data | No data | EPA 1980; NLM 2020
Odor threshold:
Water | 0.041 mg/L | | | Verschueren 1983
Air | 1.8×10^−2^ ppm | No data | No data | Fazzalari 1978
Solubility:
Water | 200 µg/L at 20°C | 50 mg/L; 0.25–0.26 ppm | No data | EPA 1981
Organic solvents | Acetone:17 g/100 mL; benzene 13.8 g/100 mL; carbon tetrachloride: 3.3 g/100 mg/L; hexane: 7.1 g/100 mL; xylene: 18.3 g/100 mL | No data | No data | Budavari 1989; NLM 2020
Partition coefficients:
Log K_ow_ | 5.6, 5.34 (calculated), 5.45 (calculated) | 3.146, 4.7, 5.6 (calculated) | 4.99 (calculated) | EPA 1981, 1995a; NLM 2020
K_oc_ | 4.532 (calculated); 5.195 (±0.005) | 4.80 (calculated); 3.929–4.653 (calculated) | No data | De Bruijin et al. 1989; Kenaga 1980; NLM 2020
Vapor pressure | 2.0×10^−7^ mmHg | 2.0×10^−7^ mmHg | No data | EPA 1981; NLM 2020; Worthing and Walker 1983
Henry’s law constant | 4.0×10^−7^ atm-m^3^/mol (calculated); 5.4×10^−7^ atm-m^3^/mol (calculated) | 2×10^−9^ atm-m^3^/mol; 2.9×10^−9^ atm-m^3^/mol; 3.67×10^−8^ atm-m^3^/mol (calculated) | 2.02×10^−8^ atm-m^3^/mol | EPA 1981; NLM 2020; EPA 1994; Thomas 1982
Autoignition temperature | No data | No data | No data
Flashpoint | Non-flammable | Non-flammable | No data | NLM 2020
Flammability limits | No data | No data | No data
Conversion factors | 1 ppm=15.6 mg/m^3^ | 1 ppm=15.6 mg/m^3^ | 1 ppm=15.6 mg/m^3^
Conversion factors | 1 mg/m^3^=0.06 ppm | 1 mg/m^3^=0.06 ppm | 1 mg/m^3^=0.06 ppm
Explosive limits | No data | No data | No data