# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute inhalation MRL.

Rationale for Not Deriving an MRL: The limited number of human studies available do not contain quantitative data needed for MRL derivation and often report co-exposure to other chemicals (e.g., aldrin, dieldrin). Acute inhalation data in laboratory animals are limited to one study reporting brain lesions and mortality in a single cat exposed twice to endrin at 417 ppm (1 hour/session) (Ressang et al. 1959).

Agency Contacts (Chemical Manager): Susan Zells Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: The limited number of human studies available do not contain quantitative data needed for MRL derivation and often report co-exposure to other chemicals (e.g., aldrin, dieldrin). The intermediate-duration inhalation database in laboratory animals consists of a single study evaluating survival in cats, guinea pigs, hamsters, rats, rabbits, and mice exposed to endrin at 0.36 ppm for 107–130 days (5 days/week, 7 hours/day) (Treon et al. 1955). Necropsy was only performed on animals that died (1/3 mice, 2/4 rabbits), and no controls were used.

Agency Contacts (Chemical Manager): Susan Zells Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: The limited number of human studies available do not contain quantitative data needed for MRL derivation and often report co-exposure to other chemicals (e.g., aldrin, dieldrin). No chronic-duration inhalation studies in laboratory animals were identified for endrin.

Agency Contacts (Chemical Manager): Susan Zells Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.0006 mg/kg/day
Critical Effect: | Decreased locomotor activity
Reference: | Kavlock et al. 1981
Point of Departure: | BMDL_1SD_ of 0.057 mg/kg
Uncertainty Factor: | 100
LSE Graph Key: | 13
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.0006 mg/kg/day was derived for endrin based on evidence of neurotoxicity (decreased locomotor activity) in rats following a single exposure to endrin at gavage doses ≥0.5 mg/kg (Kavlock et al. 1981). The MRL is based on the BMDL1SD of 0.057 mg/kg for depressed locomotor activity and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: The lowest LOAELs identified in the acute oral database include a serious LOAEL of 0.3 mg/kg/day for a 38% decrease in maternal body weight gain in rats exposed to endrin for 14 days during gestation (Kavlock et al. 1981), a LOAEL of 0.5 mg/kg/day for decreased locomotion in female rats on day 1 of a 14-day exposure (Kavlock et al. 1981), and a LOAEL of 0.5 mg/kg/day for increased liver weights in maternal rats exposed to endrin for 11 days during gestation (Kavlock et al. 1981). A NOAEL of 0.15 mg/kg/day was established for maternal body weight effects; no NOAELs were identified for neurological or hepatic effects in the Kavlock et al. (1981) study. Other reported body weight, neurological, and hepatic effects following acute exposure to endrin are reviewed in Table A-1. Observed effects in other systems, including the developing fetus, occurred at doses ≥1 mg/kg (see Table 2-3), and were not considered as candidate critical effects. It should be noted that increased mortality occurred in female CD rats exposed to ≥0.5 mg/kg/day for up to 14 days (Kavlock et al. 1981); however, the same authors observed 100% survival in a second study of female CD rats exposed to doses up to 0.45 mg/kg/day for 14 days (Kavlock et al. 1981). In other rat strains and other species, reported lethal doses following acute exposure were ≥1.5 mg/kg.

Since decreased maternal body weight in rats, decreased locomotion in female rats, and increased maternal liver weight in mice occurred at similar doses in the various experiments conducted by Kavlock et al. (1981), all were considered for MRL derivation.

Table A-1 Summary of Candidate Critical Effects for Acute Oral MRL for Endrin

Species | Duration (route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
CD rat | 14 days; (GO) | ND | 0.5 | Depressed locomotor activity on day 1 | Kavlock et al. 1981; (range-finding)
Holtzman albino rat | 8 days, every 2–3 days; (GO) | 1 | ND | No clinical signs of neurotoxicity | Coleman et al. 1968
Holtzman albino rat | Once; (GO) | ND | 25; (serious LOAEL) | Convulsions | Lawrence et al. 1968
CD-1 mouse | Up to 11 days | 0.5 | 1.5 | Decreased locomotor activity on days 1 and 3 | Kavlock et al. 1981; (range-finding)
Golden Syrian hamster | Once; GD 8; (GO) | 7.5 | 10; (serious LOAEL) | Convulsions | Chernoff et al. 1979
Hepatic effects
CD rat | 14 days; GDs 7–20; (GO) | 0.45 | | No change in maternal liver weight | Kavlock et al. 1981; (main study)
CD-1 mouse | 11 days; GDs 7–17; (GO) | ND | 0.5 | Increased relative maternal liver weight | Kavlock et al. 1981; (main study)
Holtzman albino rat | 8 days, every 2–3 days | 1 (TWA) | ND | No change in liver weight | Coleman et al. 1968
Sprague-Dawley rat | Once; (GO) | ND | 3 | Increased relative liver weight | Bagchi et al. 1992a, 1992b, 1992c
Golden Syrian hamster | 10 days; GDs 5–14; (GO) | 3.5 | ND | No change in liver weight | Chernoff et al. 1979
Sprague-Dawley rat | Once; (GO) | 4 | ND | No change in liver weight | Numan et al. 1990a
Sprague-Dawley rat; Swiss Webster mouse; guinea pig; golden Syrian hamster | Once; (GO) | ND | 4 | Necrosis, fatty degeneration, inflammation, cell regeneration, lipid peroxidation | Hassan et al. 1991
Sprague-Dawley rat | 1–2 days; (F) | | 8.2 | Altered serum chemistry, vacuolization, fatty infiltration | Ali and Shakoori 1993
Body weight effects
CD rat | 14 days; GDs 7–20; (GO) | 0.15 | 0.3; (serious LOAEL) | 38% decrease in maternal body weight gain | Kavlock et al. 1981; (main study)
Sherman rat | 10 days; GDs 6–15; (G) | 0.5 | 2 | 12% decrease in maternal weight gain (2/25 dams died at this dose) | Goldenthal 1978a
CD-1 mouse | 11 days; GDs 7–17; (GO) | 0.5 | 1; (serious LOAEL) | 24% decrease in maternal body weight gain | Kavlock et al. 1981; (main study)
CD-1 mouse | 11 days; (GO) | 0.5 | 1.5; (serious LOAEL) | 43% decrease in body weight gain | Kavlock et al. 1981; (range-finding)
Golden Syrian hamster | 10 days; GDs 5–14; (GO) | ND | 1.5; (serious LOAEL) | 19-fold increase in weight loss (37% mortality rate at this dose) | Chernoff et al. 1979
C57BL/6J or DBA/2J mouse | Once; GD 12; (GO) | 6 | ND | No change in body weight in surviving dams (25% mortality at 6 mg/kg) | Hassoun and Stohs 1996b
Sprague-Dawley rat | 1–2 days; (F) | 8.2 | | | Ali and Shakoori 1993

(F) = feed; GD = gestation day; (GO) = gavage-oil; LOAEL = lowest observed adverse effect level; MRL = minimal risk level; ND = not determined; NOAEL = no-observed-adverse-effect level; TWA = time-weighted average

Selection of the Principal Study: The Kavlock et al. (1981) range finding study in rats was selected as the principal study because it identified the lowest POD (see next section) for a sensitive target of endrin toxicity.

Summary of the Principal Study:

Kavlock RJ, Chernoff N, Hanisch RC, . 1981. Perinatal toxicity of endrin in rodents. II. Fetotoxic effects of prenatal exposure in rats and mice. Toxicology 21:141–150.7281202

Kavlock et al. (1981) conducted two studies in CD rats, a preliminary range-finding study in nonpregnant females and a main teratology study in pregnant females.

Range-Finding Study. In the range finding study, groups of 5–9 nonpregnant female rats were administered doses of 0, 0.5, 1.0, 2.0, and 4.0 mg/kg/day endrin (>99% pure) via gavage in corn oil for up to 14 days. This preliminary range-finding study only evaluated mortality, body weight, and locomotor activity. Reactive locomotor activity was measured for 30 minutes on day 1 in figure-eight mazes (2–4 hours after initial dosing).

Increased mortality occurred in all treated groups, with 60% mortality at 0.5 mg/kg/day and 100% mortality at higher doses. Survival time decreased in a time-related manner. Average times-to-death at 0.5, 1.0, 2.0, and 4.0 mg/kg/day were 7.7, 5.5, 3.4, and 1.3 days, respectively. All control animals survived. Body weight gain in the two surviving rats at the lowest dose was decreased 94% compared to controls (1.8 g gained versus 32.4 g gained). Two of the six animals in the 4 mg/kg exposure group experienced convulsions within 2–4 hours of the first exposure; these animals were excluded from the locomotor activity assessment. In other treated animals, a dose-related decrease in locomotor activity was observed 2–4 hours after the first administration. Activity was significantly depressed by 40, 72, and 88% at 0.5, 1.0, and 2.0 mg/kg, respectively. The study authors reported that activity was also decreased by 88% in the four rats at 4 mg/kg/day that did not experience convulsions; however, statistics and quantitative data for this group were not reported.

Main Teratology Study. Based on findings from the range-finding study, groups of 15–32 pregnant female rats were administered doses of 0, 0.075, 0.15, 0.3, and 0.45 mg/kg/day via gavage in corn oil from GD 7 to 20. Dams were observed for mortality and maternal body weight gain was monitored. All dams were sacrificed on GD 21. At sacrifice, the uterus and liver were removed and weighed. The uterus was examined for the number of live, dead, and resorbed fetuses. The fetuses were weighed, examined for gross anomalies, and divided equally for examination for skeletal and visceral malformations and variations.

Despite 60% mortality at 0.5 mg/kg/day in the range-finding study, no mortalities occurred in the main study at doses up to 0.45 mg/kg/day (highest dose tested). The study authors did not discuss potential reasons for this apparent steep dose-response curve for lethality. However, results from the main study are consistent with findings in other rat strains, which only reported increased mortality after exposure to acute doses ≥2 mg/kg/day (Bedford et al. 1975a; Gaines 1960, 1969; Goldenthal 1978a; Numan et al. 1990b; Speck and Maaske 1958; Treon et al. 1955). Maternal body weight gain was significantly decreased by 38–87% at ≥0.3 mg/kg/day. No exposure-related changes were observed in maternal liver weight. There were exposure-related changes in fetal endpoints.

Selection of the Point of Departure: A BMDL_1SD_ of 0.057 mg/kg was selected as the POD for the acute-duration oral MRL.

In order to identify the study providing the most sensitive POD, BMD modeling was attempted for the most sensitive data for each critical endpoint identified in Table A-1: decreased locomotor activity in female rats, increased relative liver weight in mouse dams, and decreased maternal body weight in rat dams. The data for these three endpoints are presented in Tables A-2, A-3, and A-4, respectively. The data were fit to all continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2) using a benchmark response (BMR) of 1 standard deviation (locomotor activity) or 10% relative deviation (body and organ weight data). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined BMR, BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike Information Criterion (AIC) was chosen.

Table A-2 Locomotor Activity in Female Rats Following a Single Gavage Administration of Endrin

| Dose (mg/kg)
| 0 | 0.5 | 1.0 | 2.0
Locomotor activity (number of photocell beam interruptions) | 665±82 | 400±33 | 186±49 | 83±51
Mean±SD (N) | (6) | (5) | (6) | (4)

N = number; SD = standard deviation

Source: Kavlock et al. 1981

Table A-3 Relative Liver Weight in Mouse Dams Following Gavage Administration of Endrin on GDs 7–17

| Dose (mg/kg/day)
| 0 | 0.5 | 1.0 | 1.5 | 2.0
Relative maternal liver weight (%) | 6.7±1.0 | 7.2±0.6 | 7.4±0.6 | 8.1±0.7 | 7.2±NR
Mean±SD (N) | (27) | (31) | (32) | (12) | (2)

GD = gestation day; N = number; NR = not reported (no variance data reported by study authors); SD = standard deviation (SD calculated for this review from reported standard error of the mean and animal number)

Source: Kavlock et al. 1981

Table A-4 Maternal Body Weight Gain in Rat Dams Following Gavage Administration of Endrin on GDs 7–17

| Dose (mg/kg/day)
| 0 | 0.075 | 0.150 | 0.300 | 0.450
Maternal body weight gain (g) | 69.0±21.5 | 73.0±11.2 | 66.8±19.7 | 42.9±26.4 | 8.8±19.4
Mean±SD (N) | (29) | (14) | (27) | (29) | (12)

GD = gestation day; N = number; SD = standard deviation (SD calculated for this review from reported standard error of the mean and animal number)

Source: Kavlock et al. 1981

Three models provided adequate fit to the locomotor activity data (Exponential 2, 3, and 4); the remaining models did not provide adequate fit; the results of the modeling are presented in Table A-5. The BMDL_1SD_ values were sufficiently close and the model with the lowest AIC (Exponential 2) was recommended. The Exponential 2 model estimated a BMD_1SD_ of 0.075 mg/kg and BMDL_1SD_ of 0.057 mg/kg. For the maternal relative liver weight data, all but the Exponential 4, Exponential 5, and Polynomial 2-degree models provided adequate fit to the data with nonconstant variance; the model results are presented in Table A-6. The BMDLs were sufficiently close, and the Exponential 2 model with a BMD_RD10_ of 0.820 mg/kg/day and BMDL_RD10_ of 0.642 mg/kg/day were selected. None of the models (with or without the highest dose group dropped) provided adequate fit to the maternal body weight gain data.

Table A-5 Model Predictions (Constant Variance) for Locomotor Activity in Female Rats Following a Single Gavage Administration of Endrin (Kavlock et al. 1981)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2 ^d^ ^,^ ^e^ | 0.075 | 0.057 | 0.261 | 234.60 | −0.199 | −0.199
Exponential 3^d^ | 0.092 | 0.058 | 0.124 | 236.28 | −0.102 | −0.102
Exponential 4^d^ | 0.074 | 0.055 | 0.103 | 236.57 | −0.222 | −0.222
Exponential 5^d^ | | | NA | 235.91 | −0.020 | −0.020
Hill^d^ | | | NA | 235.93 | −0.067 | −0.067
Polynomial Degree 3^d^ | | | <0.0001 | 257.88 | −0.903 | 1.931
Polynomial Degree 2^d^ | | | <0.0001 | 257.88 | −0.903 | 1.930
Power^d^ | | | <0.0001 | 257.88 | −0.903 | 1.930
Linear | | | <0.0001 | 257.88 | −0.904 | 1.930

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Exponential 2).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure dose associated with a 10% relative deviation from control)

Table A-6 Model Predictions (Nonconstant Variance) for Relative Liver Weight in Female Rats Following a Single Gavage Administration of Endrin (Kavlock et al. 1981)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2 ^d^ ^,^ ^e^ | 0.820 | 0.642 | 0.253 | 228.08 | −1.13 | −0.0149
Exponential 3^d^ | 0.822 | 0.642 | 0.252 | 228.09 | −1.13 | −0.0257
Exponential 4^d^ | | | 0.096 | 230.10 | −1.21 | 0.0609
Exponential 5^d^ | | | 0.096 | 230.11 | −1.21 | 0.0715
Hill^d^ | 0.777 | 0.592 | 0.248 | 228.12 | −1.24 | 0.099
Polynomial Degree 3^d^ | 0.851 | 0.605 | 0.106 | 229.95 | −1.02 | −0.085
Polynomial Degree 2^d^ | | | 0.097 | 230.09 | −1.16 | 0.0097
Power^d^ | 0.790 | 0.602 | 0.250 | 228.10 | −1.21 | 0.0625
Linear | 0.790 | 0.601 | 0.250 | 228.10 | −1.21 | 0.0625

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Exponential 2).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure dose associated with a 10% relative deviation from control)

The candidate PODs are summarized in Table A-7. Neurological effects in female rats (0.075 mg/kg) had the lowest effect level (BMD or LOAEL). The BMD_1SD_ for this endpoint is 0.057 mg/kg estimated using the Exponential 2 model which is presented in Figure A-1. The POD is 5 times lower than the LOAEL for decreased maternal body weight gain and nearly 10 times lower than the lethal dose reported in the range-finding study by Kavlock et al. (1981). Furthermore, the central nervous system is the primary target system for endrin toxicity (Other Additional Studies or Pertinent Information below).

Table A-7 Summary of Candidate Critical Effects and PODs for the Acute Oral MRL for Endrin

Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | BMD (mg/kg/day) | BMDL (mg/kg/day)
Decreased locomotor activity on day 1 in rats (Kavlock et al. 1981) | ND | 0.5 | 0.075 (BMD_1SD_) | 0.057^a^ (BMDL_1SD_)
Increased relative liver weight in mouse dams (Kavlock et al. 1981) | ND | 0.5 | 0.82 (BMD_RD10_) | 0.642 (BMDL_RD10_)
Decreased maternal body weight gain in rat dams (Kavlock et al. 1981) | 0.15 | 0.3; (serious LOAEL) | NA | NA

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NA = not applicable; NOAEL = no-observed-adverse-effect level; POD = point of departure; RD = relative deviation; SD = standard deviation

Figure A-1 Fit of Exponential 2 Model (with Constant Variance) for Decreased Locomotor Activity in Rats Administered Endrin on Day 1 (Kavlock et al. 1981)

Figure A-1 description

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_1SD_ ÷ uncertainty factors 0.057 mg/kg/day ÷ ( 10 × 10 ) = 0.00057 mg/kg/day ≈ 0.0006 mg/kg/day

Other Additional Studies or Pertinent Information: The POD based on neurological effects (BMDL_1SD_ of 0.057 mg/kg/day) is 5 times lower than the LOAEL for decreased maternal body weight gain and nearly 10 times lower than the lethal dose reported in the range-finding study by Kavlock et al. (1981), resulting in an MRL that is 500–1,000 times lower than any doses associated with adverse health effects or mortality. Therefore, the MRL based on neurological effects is protective of other known endpoints. Identification of neurotoxicity as the critical effect of endrin is supported by reports of neurologic effects including convulsions and tremors in humans acutely poisoned with endrin (Carbajal-Rodriquez et al. 1990; Coble et al. 1967; Curley et al. 1970; Davies and Lewis 1956; Rowley et al. 1987; Waller et al. 1992; Weeks 1967) and various animal species following oral exposure (Chernoff et al. 1979; Deichmann et al. 1970; Kavlock et al. 1981; Kettering 1969; Mehrotra et al. 1989; Treon et al. 1955). Acute neurotoxic effects have also been observed following high occupational exposure (Hoogendam et al. 1962, 1965). There is also limited animal evidence for neurotoxicity following acute inhalation or dermal exposure (Gaines 1960; Pandy 1978; Ressang et al. 1959; Treon et al. 1955).

Agency Contacts (Chemical Manager): Susan Zells Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Duration: | Intermediate
MRL: | 0.0006 mg/kg/day (adopt acute oral MRL)
Critical Effect: | Decreased locomotor activity
Reference: | Kavlock et al. 1981
Point of Departure: | BMDL_1SD_ of 0.057 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 13
Species: | Rat

MRL Summary: The acute-duration oral MRL of 0.006 mg/kg/day based on a BMDL_1SD_ of 0.057 mg/kg decreased locomotor activity in rats (Kavlock et al. 1981) was adopted for the intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: An MRL was not derived for intermediate-duration oral exposure because the MRL derived from the available data in the limited database would be higher than the acute-duration MRL. The acute-duration MRL is expected to be protective of intermediate-duration exposures; therefore, the acute oral MRL is adopted as the intermediate oral MRL.

The intermediate-duration oral database for endrin is limited (see Table A-8). The lowest identified effect level is for altered habituation in locomotor testing in PND 16 and 20 offspring following maternal exposure to 0.15 mg/kg/day endrin via gavage from GD 7 to PND 15 (Gray et al. 1981). Young and Mehendale (1986) reported hepatic LOAELs at slightly higher doses based on altered hepatic enzyme levels or hepatobiliary function in rats exposed to endrin, endrin aldehyde, or endrin ketone at 0.25–0.5 mg/kg/day for 15 days (Young and Mehendale 1986). The only other available studies reported serious LOAELs for death in one dog exposed to endrin doses of 0.20–0.27 mg/kg/day for 47 days (midpoint 0.24 mg/kg/day) (Treon et al. 1955) and mouse dams exposed to 0.65 mg/kg/day during gestation (Good and Ware 1969).

Table A-8 Summary of Effects Following Intermediate Oral Exposure to Endrin

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Sublethal effects
CD rat | 28 days; GD 7–PND 15; (GO) | 0.075^a^ | 0.15 | Altered habituation in locomotor testing in offspring on PND 16 and 20 | Gray et al. 1981
Sprague-Dawley rat | 15 days (F) | ND | 0.25 | Altered hepatobiliary function (no change in serum chemistry; organ weight and histology not assessed) | Young and Mehendale 1986
Sprague-Dawley rat | 15 days (F) | ND | 0.5 (endrin aldehyde) | 10-fold increase in serum ALT and 5-fold increase in serum AST (no changes in hepatobiliary function; organ weight and histology not assessed) | Young and Mehendale 1986
Sprague-Dawley rat | 15 days (F) | ND | 0.25 (endrin ketone) | 8-fold increase in serum ALT (no changes in hepatobiliary function; organ weight and histology not assessed) | Young and Mehendale 1986
Lethality
Beagle dog | Up to 9.9 months; 6 days/week (F) | NA | 0.23 | Death | Treon et al. 1955
Swiss mouse | 120 days (F) | NA | 0.65 | Maternal death | Good and Ware 1969

a Selected POD.

ALT = alanine aminotransferase; AST = aspartate aminotransferase; F = feed; GD = gestation day; GO = gavage-oil; LOAEL = lowest observed adverse effect level; MRL = minimal risk level; NA = not applicable; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; POD = point of departure

Altered locomotion in offspring from the Gray et al. (1981) study was selected as the critical effect because it was the most sensitive effect observed in available studies. BMD modeling was conducted for locomotor data from the final 15 minutes of the 45-minute locomotor trial, which showed the most significant increases in locomotion compared with control (Table A-9). Values for modeling were extracted from Figure 3B in the report using GrabIt! software. Using the BMD modeling approach described in the acute-duration oral MRL worksheet, no adequate models were identified with either the full dataset or the highest dose dropped. Therefore, the NOAEL of 0.075 mg/kg/day was selected as the point-of-departure. Using a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability), the intermediate-duration oral MRL would be 0.0008 mg/kg/day. This value is higher than the acute-duration oral MRL of 0.0006 mg/kg/day based on a BMDL_1SD_ of 0.057 mg/kg/day for decreased activity in adult female rats (Kavlock et al. 1981). Therefore, there are no sufficient low-dose data to derive an intermediate-duration oral MRL.

Table A-9 Locomotor Activity in PND 16–20 Rat Offspring Following Maternal Exposure to Endrin from GD 7 to PND 15 via Gavage

| Dose (mg/kg/day)
| 0 | 0.075 | 0.15 | 0.3
Locomotor activity (number of photocell beam interruptions); Mean±SD^a^ (N) | 43±8; (35) | 39±6; (34) | 71±10; (34) | 83±13; (8)

a Values extracted from graphically presented data (Figure 3B) using GrabIt! Software.

GD = gestation day; N = number; PND = postnatal day; SD = standard deviation

Source: Gray et al. 1981

Agency Contacts (Chemical Manager): Susan Zells Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endrin
CAS Numbers: | 72-20-8
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.0003 mg/kg/day
Critical Effect: | Hepatic lesions and occasional convulsions
Reference: | Kettering 1969
Point of Departure: | NOAEL of 0.025 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 52
Species: | Dog

MRL Summary: A chronic oral MRL of 0.0003 mg/kg/day was derived for endrin based on convulsions and hepatic lesions in dogs exposed to dietary endrin for 2 years (Kettering 1969). The MRL is based on the NOAEL of 0.025 mg/kg/day for neurological and hepatic effects and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: The lowest LOAEL identified in the chronic oral database was 0.05 mg/kg/day in dogs exposed to dietary endrin for 2 years (Kettering 1969). Effects observed at this dose included hepatic vacuolation in female dogs and occasional convulsions in one female dog; hepatic and neurological effects were also observed in males at the next dose (0.1 mg/kg/day). Other reported hepatic and neurological effects following chronic exposure to endrin are reviewed in Table A-10. Observed effects in other systems occurred at doses ≥0.1 mg/kg.

Table A-10 Summary of Candidate Critical Effects for Chronic Oral MRL for Endrin

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Beagle dog | 2 years (F) | 0.025^a^ (females); 0.05 (males) | 0.05 (females); 0.10 (males); (serious LOAEL) | Occasional convulsions | Kettering 1969
Beagle dog | 64–156 weeks (F) | ND | 0.059; (serious LOAEL) | Seizures | Kettering 1971
Beagle dog | 16.4–18.7 months; 6 days/week (F) | 0.12 | ND | | Treon et al. 1955
Carworth rat | 2 years (F) | 0.25 | 1.25; (serious LOAEL) | Diffuse degeneration of the brain | Treon et al. 1955
Osborne-Mendel rat | 17.6–20.8 months (F) | ND | 0.1; (serious LOAEL) | Convulsions and tremors | Deichmann et al. 1970
Osborne-Mendel rat | 80 weeks (F) | 0.3 | ND | | NCI 1979
B5C3F1 mouse | 80 weeks (F) | ND | 0.21 M; 0.33 F | Hyperexcitability | NCI 1979
Hepatic effects
Beagle dog | 2 years (F) | 0.025^a^ (females); 0.05 (males) | 0.05 (females); 0.10 (males) | Hepatic cell vacuolation | Kettering 1969
Beagle dog | 64–156 weeks (F) | 0.059 | ND | | Kettering 1971
Carworth rat | 2 years (F) | 0.05 | 0.25 | Increased liver weight | Treon et al. 1955
Osborne-Mendel rat | 17.6–20.8 months (F) | ND | 0.1 | Cloudy swelling of centrilobular cells | Deichmann et al. 1970
Osborne-Mendel rat | 80 weeks (F) | 0.3 | ND | | NCI 1979
B6C3F1 mouse | 80 weeks (F) | 0.42 | ND | | NCI 1979

a Selected POD.

(F) = feed; LOAEL = lowest observed adverse effect level; MRL = minimal risk level; ND = not determined; NOAEL = no-observed-adverse-effect level; POD = point of departure

While convulsions only occurred in one of six dogs at 0.05 mg/kg/day, neurological effects were considered co-critical effects (along with hepatic effects) because the central nervous system is the primary target system for endrin, as evidenced by reports of neurologic effects including convulsions and tremors in humans and other animal species (Curley et al. 1970; Deichmann et al. 1970; Kettering 1969; Treon et al. 1955; Waller et al. 1992).

Selection of the Principal Study: The study with the lowest candidate POD (Kettering 1969) was selected as the principal study.

Summary of the Principal Study:

Kettering Laboratory. 1969. Effects exerted upon beagle dogs during a period of two years by the introduction of 1,2,3,4,10,10-hexachloro-6,7- epoxy-1,4,4a,5,6,7,8,8a-octahydro-1,4-endo, endo-5,8-dimethanonaphthalene into their daily diets. Cincinnati, OH. Report to Velsicol Chemical Corporation.

Groups of Beagle dogs (3/sex/group) were fed diets containing 0, 0.1, 0.5, 1.0, 2.0, or 4.0 ppm endrin for 2 years. Additional animals (4/sex/group) were included in the 0-, 1.0-, and 4.0-ppm groups for interim sacrifice at 6 or 12 months (2/sex/group at each sacrifice). Using assumed food consumption of 0.32 kg feed/day and body weights of 12.7 kg, estimated daily endrin intake levels were calculated to be 0.0025, 0.125, 0.025, 0.05, and 0.1 mg/kg/day for the 0.1, 0.5, 1.0, 2.0, and 4.0 ppm dose groups, respectively. Dogs were observed daily for clinical signs of toxicity, and body weights were recorded weekly. Blood was collected for hematological and clinical chemistry evaluation at 2 weeks and 1, 3, 6, 12, 18, and 24 months. Urine was collected for analysis at the same intervals. After 24 months, all females and two males/group were sacrificed (the remaining male/group was retained for a special reproductive study, results of this study not included in this report). The liver, heart, lungs, kidneys, spleen, brain, gonads, pituitary, adrenals, and thyroid were weighed. The authors also microscopically examined these organs, along with the gall bladder, aorta, stomach, duodenum-pylorus, small and large intestines, pancreas, mesenteric lymph nodes, urinary bladder, prostate, uterus, thymus, spinal cord, eyes, bone marrow, bone, skeletal muscle, fat tissue, and skin.

The authors reported no deaths and no exposure-related changes in rate of growth, food consumption, hematology, clinical chemistry, or urinalysis.

Convulsions (or physical evidence of having had a convulsion) were observed in one female and two male dogs at 0.1 mg/kg/day and one female dog at 0.05 mg/kg/day. The study authors indicate that the female from the 0.05 mg/kg/day group convulsed on two successive days after eating at 25 months (this is unclear, since animals were scheduled for sacrifice after 24 months). At 0.1 mg/kg/day, one male showed physical evidence of having had a convulsion after 5 months (not observed at any other time point), a second male dog had several convulsions between 10 and 12 months of feeding (scheduled for interim sacrifice at 12 months), and a female dog “probably” had a convulsion at 12 and 21 months and had multiple observed convulsions at 23 months. Petechial hemorrhages and cerebral edema were observed in the brain of one male dog having convulsions at the time of necropsy.

The study observed hepatic effects at the gross and microscopic levels. There were occasional slight increases in the absolute weight of livers from dogs fed diets containing endrin at 0.05 and 0.1 mg/kg/day, compared with control; however, average weights remained within 10% of control. Relative liver weights at 0.05 and 0.1 mg/kg/day were decreased by 3 and 17% in males, respectively, and increased by 24 and 2% in females, respectively. No other potentially exposure-related organ weight changes were observed. All dogs exposed to 0.1 mg/kg/day endrin showed moderate vacuolar degeneration in the hepatic cells with diffuse brown pigment. One female exposed to 0.05 mg/kg/day also showed vacuolar degeneration and pigmentation, and one male exposed to 0.05 showed brown pigmentation without vacuolar degeneration. Concentrations of 0.05 and 0.1 mg/kg/day endrin were associated with slight to moderate vacuolation of hepatic cells.

Based on hepatic and neurological effects, a NOAEL of 0.025 mg/kg/day and a LOAEL of 0.05 mg/kg/day were identified for this study.

Selection of the Point of Departure: The NOAEL of 0.025 mg/kg/day for neurological and hepatic effects was selected as the POD.

Due to the small number of animals per group (3/sex/group), the data were considered inadequate for BMD modeling. Thus, the NOAEL/LOAEL approach was used to identify the POD.

Uncertainty Factor: The NOAEL is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ uncertainty factors 0.025 mg/kg/day ÷ ( 10 × 10 ) = 0.00025 ≈ 0.0003 mg/kg/day

Other Additional Studies or Pertinent Information: The central nervous system is the primary target system for endrin as evidenced by reports of neurologic effects including convulsions and tremors in humans acutely poisoned with endrin (Carbajal-Rodriquez et al. 1990; Coble et al. 1967; Curley et al. 1970; Davies and Lewis 1956; Rowley et al. 1987; Waller et al. 1992; Weeks 1967) and various animal species following oral exposure (Chernoff et al. 1979; Deichmann et al. 1970; Kavlock et al. 1981; Kettering 1969; Mehrotra et al. 1989; Treon et al. 1955). Acute neurotoxic effects have also been observed following high occupational exposure (Hoogendam et al. 1962, 1965). Limited animal evidence also reports neurotoxicity following acute inhalation or dermal exposure (Gaines 1960; Pandy 1978; Ressang et al. 1959; Treon et al. 1955).

The liver also appears to be a potential toxicity target of endrin. In laboratory animals, hepatic effects been consistently reported following inhalation, oral, or dermal exposure at or near lethal levels in several species, including increased liver weight, altered liver serum enzymes, diffuse degenerative lesions, necrosis, vacuolation, fatty degeneration, and lipid peroxidation (Ali and Shakoori 1993; Bagchi et al. 1992a, 1992b, 1992c; Hassan et al. 1991; Hassoun et al. 1993; Kavlock et al. 1981; Lawrence et al. 1968, Treon et al. 1955; Young and Mehendale 1986). In low-dose oral chronic studies, hepatic effects were reported at sublethal effects in rats and dogs, including increased liver weight, cloudy swelling of centrilobular cells, and vacuolation (Deichmann et al. 1970; Kettering 1969; Treon et al. 1955).

Agency Contacts (Chemical Manager): Susan Zells Ingber