# 9 REFERENCES

*Not cited in text

Abadin HG, Chou SHSJ, Llados FT. 2007. Health effects classification and its role in the derivation of minimal risk levels: Immunological effects. Regul Toxicol Pharmacol 47:249–256.
Abalis IM, Eldefrawi ME, Eldefrawi AT. 1986. Effects of insecticides on GABA-induced chloride influx into rat brain microsacs. J Toxicol Environ Health 18:13–23.3009836
ACGIH. 2014. Endosulfan. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 28, 72–72.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agarwal DK, Seth PK, Gupta PK. 1978. Effect of endosulfan on drug metabolizing enzymes and lipid peroxidation in rat. J Environ Sci Health C13(1):49–49.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
Agrawal AK, Anand M, Zaidi NF, . 1983. Involvement of serotonergic receptors in endosulfan neurotoxicity. Biochem Pharmacol 32:3591–3593.6686038
Ahmed T, Pathak R, Mustafa MD, . 2011. Ameliorating effect of N-acetylcysteine and curcumin on pesticide-induced oxidative DNA damage in human peripheral blood mononuclear cells. Environ Monit Assess 179(1–4):293–299.21049288
AIHA. 2014. Current ERPG values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/getinvolved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. March 4, 2015.
Alamgir Zaman Chowdhury M, Fakhruddin ANM, Nazrul Islam M, . 2013. Detection of the residues of nineteen pesticides in fresh vegetable samples using gas chromatography-mass spectrometry. Food Control 34(2):457–465.
Aleksandrowicz DR. 1979. Endosulfan poisoning and chronic brain syndrome. Arch Toxicol 43:65–68.533363
Ali M, Kazmi AA, Ahmed N. 2014. Study on effects of temperature, moisture and pH in degradation and degradation kinetics of aldrin, endosulfan, lindane pesticides during full-scale continuous rotary drum composting. Chemosphere 102:68–75.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Alva S, Damodar D, D’Souza A, . 2012. Endosulfan induced early pathological changes in vital organs of rat: A biochemical approach. Indian J Pharmacol 44(4):512–515.
Alvarado-Hernandez DL, Montero-Montoya R, Serrano-Garcia L, . 2013. Assessment of exposure to organochlorine pesticides and levels of DNA damage in mother-infant pairs of an agrarian community. Environ Mol Mutagen 54(2):99–111.23355095
Aly HA, Khafagy RM. 2014. Taurine reverses endosulfan-induced oxidative stress and apoptosis in adult rat testis. Food Chem Toxicol 64:1–9.
Amann RP. 1982. Use of animal models for detecting specific alterations in reproduction. Fundam Appl Toxicol 2:13–26.
Andersen HR, Andersson AM, Arnold SF, . 1999. Comparison of short-term estrogenicity tests for identification of hormone-disrupting chemicals. Environ Health Perspect 107(Suppl 1):89–108.
Andersen HR, Vinggaard AM, Rasmussen TH, . 2002. Effects of currently used pesticides in assays for estrogenicity, androgenicity, and aromatase activity in vitro. Toxicol Appl Pharmacol 179(1):1–12.11884232
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987a. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andrascikova M, Hrouzkova S, Cunha SC. 2013. Combination of QuEChERS and DLLME for GC-MS determination of pesticide residues in orange samples. Food Addit Contam, Part A: 30(2):286–297.
Ansari RA, Husain K, Gupta PK. 1987. Endosulfan toxicity influence on biogenic amines of rat brain. J Environ Biol 8:229–236.
Ansari RA, Siddiqui MKJ, Gupta PK. 1984. Toxicity of endosulfan: Distribution of alpha- and beta- isomers of racemic endosulfan following oral administration in rats. Toxicol Lett 21:29–33.6719484
Antherieu S, Ledirac N, Luzy AP, . 2007. Endosulfan decreases cell growth and apoptosis in human HaCaT keratinocytes: Partial ROS-dependent ERK1/2 mechanism. J Cell Physiol 213(1):177–186.17503468
Arcaro KF, Vakharia DD, Yang Y, . 1998. Lack of synergy by mixtures of weakly estrogenic hydroxylated polychlorinated biphenyls and pesticides. Environ Health Perspect 106(Suppl. 4):1041–1046.9703490
Armitage JM, Gobas FA. 2007. A terrestrial food-chain bioaccumulation model for POPs. Environ Sci Technol 41(11):4019–4025.17612184
Arrebola FJ, Martinex Vidal JL, Fernández-Gutierrez A. 1999. Excretion study of endosulfan in urine of a pest control operator. Toxicol Lett 107:15–20.10414777
Aschengrau A, Coogan PF, Quinn MM, . 1998. Occupational exposure to estrogenic chemicals and the occurrence of breast cancer: An exploratory analysis. Am J Ind Med 34:6–14.9617382
Ata A, Hatipoglu FS, Yildiz-Gulay O, . 2007. Protective role of ascorbic acid on subacute sperm toxicity in male New Zealand white rabbits treated with endosulfan. Drug Chem Toxicol 30(3):181–195.17613005
Awasthi N, Manickam N, Kumar A. 1997. Biodegradation of endosulfan by a bacterial coculture. Bull Environ Contam Toxicol 59(6):928–934.9400664
Ayub S, Verma J, Das N. 2003. Effect of endosulfan and malathion on lipid peroxidation, nitrite and TNF-alpha release by rat peritoneal macrophages. Int Immunopharmacol 3(13–14):1819–1828.14636831
Bajpayee M, Pandey AK, Zaidi S, . 2006. DNA damage and mutagenicity induced by endosulfan and its metabolites. Environ Mol Mutagen 47(9):682–692.16933317
Balasubramaniam E, Paul V, Jayakumar AR, . 1996. The effect of chronic cyclodiene insecticide treatment on some pharmacological actions of diazepam in rats. Environ Toxicol Pharmacol (2):141–141.
Banerjee BD, Hussain QZ. 1986. Effect of sub-chronic endosulfan exposure on humoral and cell-mediated immune responses in albino rats. Arch Toxicol 59:279–284.3827596
Banerjee BD, Hussain QZ. 1987. Effects of endosulfan on humoral and cell-mediated immune responses in rats. Bull Environ Contam Toxicol 38:435–441.3814868
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barooah I, Murthy PS, Mukherjee SK. 1980. Nature of endosulfan induced blood sugar lowering. Indian J Exp Biol 18:1446–1447.7228134
Beauvais SL, Silva MH, Powell S. 2010a. Human health risk assessment of endosulfan. Part IV: Occupational reentry and public non-dietary exposure and risk. Regul Toxicol Pharmacol 56(1):38–50.19733201
Beauvais SL, Silva MH, Powell S. 2010b. Human health risk assessment of endosulfan. Part III: Occupational handler exposure and risk. Regul Toxicol Pharmacol 56(1):28–37.19854234
Bennett DA, Chung AC, Lee SM. 1997. Multiresidue method for analysis of pesticides in liquid whole milk. J AOAC Int 80(5):1065–1077.9325583
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bernardelli BC, Gennari MC. 1987. Death caused by ingestion of endosulfan. J Forensic Sci 32:1109–1112.3612067
Bharath BK, Srilatha C, Anjaneyulu Y. 2011. Reproductive toxicity of endosulfan on male rats. Int J Pharmacol Bio Sci 2(3):508–512. http://www.ijpbs.net/vol-2_issue-3/bio_science/64.pdf. April 08, 2015.
*Bhatia A, Thind H, Kaur J. 1998. Effect of endosulfan on numerical values and functions of mice cells involved in immune response. J Ecotoxicol Environ Monit 8(3):257–261.
Blanco-Coronado JL, Repetto M, Ginestal RJ, . 1992. Acute intoxication by endosulfan. J Clin Toxicol 30(4):575–583.
Boereboom FT, van Dijk A, van Zoonen P, . 1998. Nonaccidental endosulfan intoxication: A case report with toxicokinetic calculations and tissue concentrations. Clin Toxicol 36(4):345–352.
Boyd EM. 1972. Endosulfan. In: Protein deficiency and pesticide toxicity. Springfield, IL: Charles C. Thomas, 195–205.
Boyd EM, Dobos I. 1969. Protein deficiency and tolerated oral doses of endosulfan. Arch Int Pharmacodyn Ther 178:152–165.5353468
Boyd EM, Dobos I, Krijnen CJ. 1970. Endosulfan toxicity and dietary protein. Arch Environ Health 21:15–19.5422318
Bradlow HL, Davis DL, Lin G, . 1995. Effects of pesticides on the ratio of 16a/2-hydroxyestrone: A biologic marker of breast cancer risk. Environ Health Perspect 103(Suppl. 7):147–150.
Braun HE, Lobb BT. 1976. Residues in milk and organs in a dairy herd following acute endosulfan intoxication. Can J Anim Sci 56:373–376.
Briz V, Molina-Molina JM, Sanchez-Redondo S, . 2011. Differential estrogenic effects of the persistent organochlorine pesticides dieldrin, endosulfan, and lindane in primary neuronal cultures. Toxicol Sci 120(2):413–427.21278053
Budavari S, ed. 1996. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 11^th^ ed. Rahway, NJ: Merck & Co., Inc., 605.
Burchat CS, Ripley BD, Leishman PD, . 1998. The distribution of nine pesticides between the juice and pulp of carrots and tomatoes after home processing. Food Addit Contam 15(1):61–71.9534872
Bury D. 1997. Neuro-toxicological screening in the male and female wistar rat - acute oral toxicity. Hoechst Mario Roussel, Preclinical Development, Germany Drug Safety, Frankfurt am Main, Germany, Report No. 97.0149; Study No. 96.0373. Submitted to U.S. Environmental Protection Agency. MRID44403101.
Cabaleiro T, Caride A, Romero A, . 2008. Effects of in utero and lactational exposure to endosulfan in prefrontal cortex of male rats. Toxicol Lett 176(1):58–67.18060705
Cable GG, Doherty S. 1999. Acute carbamate and organochlorine toxicity causing convulsions in an agricultural pilot: A case report. Aviat Space Environ Med 70(1):68–72.9895024
Caglar Y, Kaya M, Belge E, . 2003. Ultrastructural evaluation of the effect of endosulfan on mice kidney. Histol Histopathol 18(3):703–708.12792881
Cappiello A, Famiglini kG, Palma P, . 2014. Determination of selected endocrine disrupting compounds in human fetal and newborn tissues by GC-MS. Anal Bioanal Chem 406(12):2779–2788.24633505
Caride A, Lafuente A, Cabaleiro T. 2010. Endosulfan effects on pituitary hormone and both nitrosative and oxidative stress in pubertal male rats. Toxicol Lett 197(2):106–112.20471459
Casabar RC, Wallace AD, Hodgson E, . 2006. Metabolism of endosulfan-alpha by human liver microsomes and its utility as a simultaneous in vitro probe for CYP2B6 and CYP3A4. Drug Metab Dispos 34(10):1779–1785.16855053
CDPR. 2011. Summary of pesticide use report data 2010 indexed by chemical. Sacramento, CA: California Environmental Protection Agency. www.cdpr.ca.gov/docs/pur/pur10rep/chmrpt10.pdf. June 5, 2012.
*Cerkezkayabekir A, Aktac T. 1997. The histopathologic effects of endosulfan on the mouse thyroid gland. Turk J Biol 21(4):439–444.
Ceron JJ, Panizo CG, Montes A. 1995. Toxicological effects in rabbits induced by endosulfan, lindane, and methylparathion representing agricultural byproducts contamination. Bull Environ Contam Toxicol 54(2):258–265.7537992
Cerrillo I, Granada A, Lopez-Espinosa MJ, . 2005. Endosulfan and its metabolites in fertile women, placenta, cord blood, and human milk. Environ Res 98(2):233–239.15820730
Chan MP, Mohd MA. 2005. Analysis of endosulfan and its metabolites in rat plasma and selected tissue samples by gas chromatography-mass spectrometry. Environ Toxicol 20(1):45–52.15712329
Chan MP, Morisawa S, Nakayama A, . 2005. Toxicokinetics of ^14^C-endosulfan in male Sprague-Dawley rats following oral administration of single or repeated doses. Environ Toxicol 20(5):533–541.16161119
Chan MP, Morisawa S, Nakayama A, . 2006. A physiologically based pharmacokinetic model for endosulfan in the male Sprague-Dawley rats. Environ Toxicol 21(5):464–478.16944508
Chand S, Mustafa MD, Banerjee BD, . 2014. CYP17A1 gene polymorphisms and environmental exposure to organochlorine pesticides contribute to the risk of small for gestational age. Eur J Obstet Gynecol Reprod Biol 180:100–105.25064838
Chary NS, Herrera S, Gomez Maria J, . 2012. Parts per trillion level determination of endocrine-disrupting chlorinated compounds in river water and wastewater effluent by stir-bar-sorptive extraction followed by gas chromatography-triple quadrupole mass spectrometry. Anal Bioanal Chem 404(6–7):1993–2006.22850896
Chatterjee SK, Sur S, Sen U. 1986. Effect of endosulfan on glycogen content of different tissues of mice. Environ Ecol 4:500–502.
Chaudhuri K, Selvaraj S, Pal AK. 1999. Studies on the genotoxicity of endosulfan in bacterial systems. Mutat Res 439:63–67.10029677
Choudhary N, Joshi SC. 2003. Reproductive toxicity of endosulfan in male albino rats. Bull Environ Contam Toxicol 70(2):285–289.12545360
Choudhary N, Sharma M, Verma P, . 2003. Hepato and nephrotoxicity in rat exposed to endosulfan. J Environ Biol 24(3):305–308.15259607
Christensen JR, Yunker MB, MacDuffee M, . 2013. Plant consumption by grizzly bears reduces biomagnification of salmon-derived polychlorinated biphenyls, polybrominated diphenyl ethers, and organochlorine pesticides. Environ Toxicol Chem 32(5):995–1005.23401324
Chugh SN, Dhawan R, Agrawal N, . 1998. Endosulfan poisoning in Northern India: A report of 18 cases. Int J Clin Pharmacol Ther Toxicol 36(9):474–477.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cok I, Durmaz TC, Durmaz E, . 2010. Determination of organochlorine pesticide and polychlorinated biphenyl levels in adipose tissue of infertile men. Environ Monit Assess 162(1–4):301–309.19252989
Cok I, Yelken C, Durmaz E, . 2011. Polychlorinated biphenyl and organochlorine pesticide levels in human breast milk from the Mediterranean city Antalya, Turkey. Bull Environ Contam Toxicol 86(4):423–427.21340456
Cole LM, Casida JE. 1986. Polychlorocycloalkane insecticide-induced convulsions in mice in relation to disruption of the GABA-regulated chloride ionophore. Life Sci 39:1855–1862.2430161
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424.14744240
Cotham WE Jr, Bidleman TF. 1989. Degradation of malathion, endosulfan, and fenvalerate in seawater and seawater/sediment in microcosms. J Agric Food Chem 37:824–828.
Coutselinis A, Kentarchou P, Boukis D. 1978. Concentration levels of endosulfan in biological material (report of three cases). Forensic Sci 11:75.631681
Crain DA, Noriega N, Vonier PM, . 1998. Cellular bioavailability of natural hormones and environmental contaminants as a function of serum and cystolic binding factors. Toxicol Ind Health 14(1/2):261–273.9460179
Dalsenter PR, Dallegrave E, Mello JR, . 1999. Reproductive effects of endosulfan on male offspring of rats exposed during pregnancy and lactation. Hum Exp Toxicol 18(9):583–589.10523873
Dalsenter PR, de Araujo SL, de Assis HC, . 2003. Pre and postnatal exposure to endosulfan in Wistar rats. Hum Exp Toxicol 22(4):171–175.12755467
Daly GL, Wania F. 2005. Organic contaminants in mountains. Environ Sci Technol 39(2):385–398.15707037
Daly GL, Lei YD, Teixeira C, . 2007. Pesticides in western Canadian mountain air and soil. Environ Sci Technol 41(17):6020–6025.17937276
Damgaard IN, Skakkebaek NE, Toppari J, . 2006. Persistent pesticides in human breast milk and cryptorchidism. Environ Health Perspect 114(7):1133–1138.16835070
Das N, Garg A. 1981. Effect of endosulfan in female rats growing on low- and high-protein cereal diet. Pestic Biochem Physiol 15:90–98.
Das N, Srivastava N, Srivastava LM. 1988. Activation of serum complement by organochlorine insecticides, DDT and endosulfan. Curr Sci 57:524–526.
Deema P, Thompson E, Ware GW. 1966. Metabolism, storage and excretion of C-^14^-endosulfan in the mouse. J Econ Entomol 59:546–550.5932260
DeLorenzo ME, Taylor LA, Lund SA, . 2002. Toxicity and bioconcentration potential of the agricultural pesticide endosulfan in phytoplankton and zooplankton. Arch Environ Contam Toxicol 42:173–181.11815808
Demeter J, Heyndrickx A. 1978. Two lethal endosulfan poisonings in man. J Anal Toxicol 2:68–74.
Demeter J, Heyndrickx A, Timperman J, . 1977. Toxicological analysis in a case of endosulfan suicide. Bull Environ Contam Toxicol 18:110–114.884331
Demeter J, Van Peteghem C, Heyndrickx A. 1978. Determination of endosulfan in biological samples by off line high-pressure liquid chromatography-mass fragmentography. In: de Leenheer AP, Roncucci RR, van Peteghem C, eds. Quantitative mass spectrometry in life sciences II: Proceedings of the Second International Symposium State University of Ghent, June 13–16, 1978. New York, NY: Elsevier Scientific Publishing Company, 471–481.
Den Tonkelaar EM, Van Esch GJ. 1974. No-effect levels of organochlorine pesticides based on induction of microsomal liver enzymes in short-term toxicity experiments. Toxicology 2:371–380.4137085
Dikshith TSS, Datta KK. 1978. Endosulfan: Lack of cytogenetic effects in male rats. Bull Environ Contam Toxicol 20:826–833.749981
Dikshith TSS, Raizada RB. 1983. Response of carbon tetrachloride pretreated rats to endosulfan, carbaryl and phosphamidon. Ind Health 21:263–271.6418695
Dikshith TSS, Nath G, Datta KK. 1978. Combined cytogenetic effects of endosulfan and metepa in male rats. Indian J Exp Biol 16:1000–1002.721144
Dikshith TSS, Raizada RB, Kumar SN, . 1988. Effect of repeated dermal application of endosulfan to rats. Vet Hum Toxicol 30:219–224.3388749
Dikshith TSS, Raizada RB, Srivastava MK, . 1984. Response of rats to repeated oral administration of endosulfan. Ind Health 22:295–304.6526703
DOE. 2012a. Table 3: PACs by CASRN (pdf). PAC Rev 27 Tables - PAC data and chemical properties presented in pdf and excel tables. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for chemicals of concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 4, 2015.
DOE. 2012b. Protective action criteria (PAC): Chemicals with AEGLs, ERPGs, & TEELs. Definition of PACs (AEGLs, ERPGs or TEELs). Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for Chemicals of Concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 24, 2015.
Dorough HW, Huhtanen K, Marshall TC, . 1978. Fate of endosulfan in rats and toxicological considerations of apolar metabolites. Pestic Biochem Physiol 8:241–252.
Dreher RM, Podratzki B. 1988. Development of an enzyme-immunoassay for endosulfan and its degradation products. J Agric Food Chem 36:1072–1075.
Dreisbach RH, Robertson WO, eds. 1987. Handbook of poisoning: Prevention diagnosis & treatment. 12th ed. Norwalk, CT: Appleton & Lange, 108–109.
Dubois M, Pfohl-Leszkowicz A, De Waziers I, . 1996. Selective induction of the CYP3A family by endosulfan and DNA-adduct formation in different hepatic and hepatoma cells. Environ Toxicol Pharmacol 1(4):249–256.21781690
Dureja P, Mukerjee SK. 1982. Photoinduced reactions: Part IV. Studies on the photochemical fate of 6,7,8,9,10,10-hexachloro-1,5,5a,6,9,9a-hexahydro-6,9-methano-2,4,3-benzo(e)dioxathiepin-3-oxide (endosulfan), an important insecticide. Indian J Chem 21B:411–413.
Dzwonkowska A, Hubner H. 1986. Induction of chromosomal aberrations in the Syrian hamster by insecticides tested in vivo. Arch Toxicol 58:152–156.3964078
Eddleston M, Haggalla S, Reginald K, . 2007. The hazards of gastric lavage for intentional self-poisoning in a resource poor location. Clin Toxicol (Phila) 45:136–143.17364630
EI Dupont deNemours & Co. 1973. Maternal toxicity, embryotoxicity and teratogenic potential of neoprene accelerators applied to skin of rats during organogenesis. Submitted under TSCA Section 8D. OTS0556789.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
El Beit IOD, Wheelock JV, Cotton DE. 1981. Pesticide-microbial interaction in the soil. Int J Environ Stud 16:171–179.
El-Shenawy NS. 2010. Effects of insecticides fenitrothion, endosulfan and abamectin on antioxidant parameters of isolated rat hepatocytes. Toxicol in Vitro 24(4):1148–1157.20214973
Ely TS, Macfarlane JW, Galen WP, . 1967. Convulsions in thiodan workers. A preliminary report. J Occup Med 9:35–37.5226634
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Vol. I: Introduction and technical background, metals and inorganics, pesticides and PCB’s. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA440479029a, 27.12-7.16.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Final report. Washington, DC: U.S. Environmental Protection Agency. EPA440481014.
EPA. 1988. Tolerances for pesticides in foods. Endosulfan. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 185.2600.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1992. Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. Method 1656. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 821 RR-92-002. April 1992.
EPA. 1994. Method 8080A. Organochlorine pesticides and polychlorinated biphenyls by gas chromatography. U.S. Environmental Protection Agency. http://www.accustandard.com/asi/pdfs/epa_methods/8080A.pdf. June 6, 2012.
EPA. 1996a. Method 8081A. Organochlorine pesticides by gas chromatography. U.S. Environmental Protection Agency. www.caslab.com/EPA-Methods/PDF/8081a.pdf. June 6, 2012.
EPA. 1996b. Method 8270c. Semivolatile organic compounds by gas chromatography. U.S. Environmental Protection Agency. www.caslab.com/EPA-Methods/PDF/8270c.pdf. June 19, 2012.
EPA. 1996c. Methods for organic chemical analysis of municipal and industrial wastewater. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Engineering and Analysis Division. EPA821B96005.
EPA. 1997. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
EPA. 1997d. Methods and guidance for analysis of water. Method 508: Determination of chlorinated pesticides in water by gas chromatography with an electron capture detector. U.S. Environmental Protection Agency, Washington, DC. EPA 821-c-97-001.
EPA. 1997e. Methods and guidance for analysis of water. Method 508.1: Determination of chlorinated pesticides, herbicides, and organohalides by liquid-solid extraction and electron capture gas chromatography. U.S. Environmental Protection Agency, Washington, DC. EPA 821-c-97-001.
EPA. 1997f. Methods and guidance for analysis of water. Method 525.2: Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. U.S. Environmental Protection Agency, Washington, DC. EPA 821-c-97-001.
EPA. 1997h. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 2000a. Benchmark dose technical guidance document. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
EPA. 2000b. Choosing a percentile of acute dietary exposure as a threshold of regulatory concern. U.S. Environmental Protection Agency. http://www.epa.gov/oppfead1/trac/science/trac2b054.pdf. April 7, 2015.
EPA. 2001. Clean sweep report 2001. U.S. Environmental Protection Agency. EPA735R01003.
EPA. 2002. Reregistration eligibility decision for endosulfan. Washington, DC: Environmental Protection Agency. PB2004106931. www.epa.gov/oppsrrd1/REDs/endosulfan_red.pdf. May 7, 2012.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2007. Method 8081B. Organochlorine pesticides by gas chromatography. U.S. Environmental Protection Agency. http://www.epa.gov/epawaste/hazard/testmethods/sw846/pdfs/8081b.pdf. June 6, 2012.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2010a. Endosulfan: 2010. Environmental fate and ecological risk assessment. Washington, DC: U.S. Environmental Protection Agency.
EPA. 2010b. Memorandum. Endosulfan: The health effects division’s human health risk assessment. Washington, DC: U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. EPAHQOPP200202620178. http://www.regulations.gov/search/Regs/home.html#documentDetail?R=0900006480afefa3. May 7, 2012.
EPA. 2011. Endosulfan. EPI Suite results for CAS 115-29-7. EPI Suite v4.10. U.S. Environmental Protection Agency. http://www.epa.gov/opptintr/exposure/pubs/episuitedl.htm April 25, 2012
EPA. 2012a. Import and export trade requirements. U.S. Environmental Protection Agency. http://www.epa.gov/oppfead1/international/trade. March 9, 2012.
EPA. 2012b. Restricted and canceled uses. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/regulating/resrticted.htm March 14, 2012.
EPA. 2012c. Label review manual. Chapter 13: Storage and disposal. U.S. Environmental Protection Agency. http://www.epa.gov/oppfead1/labeling/lrm/chap-13.pdf. March 30, 2012.
EPA. 2012d. Method 625-Base/neutrals and acids. Methods for organic chemical analysis. U.S. Environmental Protection Agency. http://water.epa.gov/scitech/methods/cwa/organics/upload/2007_07_10_methods_method_organics_625.pdf. May 11, 2012.
EPA. 2012e. Endosulfan phase-out. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/reregistration/endosulfan/endosulfan-agreement.html. June 5, 2012.
EPA. 2012f. Benchmark dose technical guidance. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA100R12001.
EPA. 2012g. 2012 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. March 4, 2015.
EPA. 2012h. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2013a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec116-4.pdf. March 4, 2015.
EPA. 2013b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm March 4, 2015.
EPA. 2013c. Determination of reportable quantities for hazardous substances. Subpart A - General provisions. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec117-3.pdf. March 4, 2015.
EPA. 2013d. Appendix A to Part 355—The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part355-appA.pdf. September 10, 2014.
EPA. 2014a. Final AEGLs (162). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_03oct2014.pdf. March 4, 2015.
EPA. 2014b. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/index1.pdf. September 10, 2014.
EPA. 2014c. InertFinder. U.S. Environmental Protection Agency. March 31, 2015. http://iaspub.epa.gov/apex/pesticides/f?p=101:1:.
EPA. 2014d. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec302-4.pdf. March 4, 2015.
EPA. 2014e. Chemicals and chemical categories to which this part applies. Subpart D - Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec372-65.pdf. March 4, 2015.
Ernst W. 1977. Determination of the bioconcentration potential of marine organism- A steady state approach. I. Bioconcentration data for seven chlorinated pesticides in mussels (Mytilus edulis) and their relation to solubility data. Chemosphere 11:731–740.
Eyer F, Felgenhauer N, Jetzinger E, . 2004. Acute endosulfan poisoning with cerebral edema and cardiac failure. J Toxicol Clin Toxicol 42(6):927–932.15533034
Falck GCM, Hirvonen A, Scarpato R, . 1999. Micronuclei in blood lymphocytes and genetic polymorphism for GSTM1, GSTTl and NAT2 in pesticide-exposed greenhouse workers. Mutat Res 441:225–237.10333536
FAO. 2011a. FAO specifications and evaluations for agricultural pesticides. Endosulfan (1,4,5,6,7,7-hexachloro-8,9,10-trinorborn-5-en-2,3-ylenebismethylene)sulfite. Food and Agriculture Organization of the United Nations, 1–17.
FAO. 2011b. FAO Media Centre: Globe’s first line of defense against toxic chemicals strengthened. http://www.fao.org/news/story/en/item/81503/icode/. March 13, 2012.
FDA. 1994. 304: Method for fatty foods. Pesticide analytical manual, 3rd edition. Vol. 1. 304–301 to 304–334.
FDA. 1999a. 302: Method I for nonfatty foods. Pesticide analytical manual, 3rd edition. Vol. 1. 302–301 to 302–370.
FDA. 1999b. 303: Method II for nonfatty foods. Pesticide analytical manual, 3rd edition. Vol. 1. 303–301 to 303–314.
FDA. 2005. Total diet study market baskets 2004-1 through 2005-4. College Park, MD: U.S. Food and Drug Administration. http://www.fda.gov/downloads/Food/FoodSafety/FoodContaminantsAdulteration/TotalDietStudy/UCM291686.pdf. May 7, 2012.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting January 08, 2014.
Fernandez MF, Olmos B, Granada A, . 2007. Human exposure to endocrine-disrupting chemicals and prenatal risk factors for cryptorchidism and hypospadias: A nested case-control study. Environ Health Perspect 115(Suppl 1):8–14.18174944
Flores-Ramirez R, Ortiz-Perez MD, Batres-Esquivel L, . 2014. Rapid analysis of persistent organic pollutants by solid phase microextraction in serum samples. Talanta 123:169–178.24725880
FMC. 1958. Thiodan technical: Acute oral administration - dogs. Final report. Conducted for Food Machinery and Chemical Corporation, Niagara Chemical Division. Hazleton Laboratories, Inc., Falls Church, VA.
FMC. 1959a. Thiodan technical: Repeated oral administration - dogs. Final report. Conducted for Food Machinery and Chemical Corporation, Niagara Chemical Division. Hazleton Laboratories, Inc., Falls Church, VA.
FMC. 1959b. Thiodan technical: Two-year chronic feeding study - rats. Final report. Conducted for Food Machinery and Chemical Corporation, Niagara Chemical Division. Hazleton Laboratories, Inc., Falls Church, VA.
FMC. 1965. Three-generation reproduction study in albino rats on thiodan: Results through weaning of F1b litters. Conducted for Food Machinery and Chemical Corporation, Niagara Chemical Division. Industrial Bio-Test Laboratories, Inc., Northbrook, IL.
FMC. 1967. Two-year chronic oral toxicity of thiodan technical - Beagle dogs. Conducted for Food Machinery and Chemical Corporation. Industrial Bio-Test Laboratories, Inc., Northbrook, IL.
FMC. 1972. Teratogenic study with thiodan technical in albino rats. Conducted for Food Machinery and Chemical Corporation, Niagara Chemical Division. Industrial Bio-Test Laboratories, Inc., Northbrook, IL.
FMC. 1980. Final report: Teratology study with FMC 5462 in rats. Conducted for Food Machinery and Chemical Corporation. Raltech Scientific Services, Madison, WI. Raltech study no. 79041.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
*Fransson-Steen R, Warngard L. 1992. Inhibitory effects of endosulfan on gap junctional intercellular communication in WB-F344 rat liver cells and primary rat hepatocytes. Carcinogenesis 13(4):657–662.1374295
Fransson-Steen R, Flodstrom S, Warngard L. 1992. The insecticide endosulfan and its two stereoisomers promote the growth of altered hepatic foci in rats. Carcinogenesis 13(12):2299–2303.1473237
Freire C, Koifman RJ, Sarcinelli P, . 2012. Long term exposure to organochlorine pesticides and thyroid function in children from Cicade dos Meninos, Rio de Janeiro, Brazil. Environ Res 117:68–74.22776325
Freire C, Koifman RJ, Sarcinelli PN, . 2013. Long-term exposure to organochlorine pesticides and thyroid status in adults in a heavily contaminated area in Brazil. Environ Res 127:7–15.24183346
Freire C, Koifman RJ, Sarcinelli PN, . 2014. Association between serum levels of organochlorine pesticides and sex hormones in adults living in a heavily contaminated area in Brazil. Int J Hyg Environ Health 217(2–3):370–378.23972672
Freire C, Lopez-Espinosa MJ, Fernandez M, . 2011. Prenatal exposure to organochlorine pesticides and TSH status in newborns from southern Spain. Sci Total Environ 409(18):3281–3287.21683986
Frevert J, Zietz E, Knoell HE. 1988. Residue- and groundwater analysis: New techniques. Brighton Crop Protection Conference - Pests and Diseasex, 727–731.
Fricke RF. 1998. Memorandum: Endosulfan 079401 - Acute neurotoxicity study in rats. DP Barcode: D240294; Submission No.: S532496; PC Code: 079401. Submitted to U.S. Environmental Protection Agency. MRID44403101.
Gale RW, Cranor WL, Alvarez DA, . 2009. Semivolatile organic compounds in residential air along the Arizona-Mexico border. Environ Sci Technol 43(9):3054–3060.19534113
Gant DB, Eldefrawi ME, Eldefrawi AT. 1987. Cyclodiene insecticides inhibit GABA receptor-regulated chloride transport. Toxicol Appl Pharmacol 88:313–321.3033845
Garcia-Rodriquez J, Garcia-Martin M, Nogueras-Ocana M, . 1996. Exposure to pesticides and cryptorchidism: Geographical evidence of a possible association. Environ Health Perspect 104(10):1090–1095.8930551
Garg A, Kunwar K, Das N, . 1980. Endosulfan intoxication: Blood glucose, electrolytes, Ca levels, ascorbic acid and glutathione in rats. Toxicol Lett 5:119–123.7466837
Gelsleichter J, Manire CA, Szabo NJ, . 2005. Organochlorine concentrations in bonnethead sharks (Sphyrna tiburo) from four Florida estuaries. Arch Environ Contam Toxicol 48(4):474–483.15883671
Gilbert ME. 1992. A characterization of chemical kindling with the pesticide endosulfan. Neurotoxicol Teratol 14(2):151–158.1593989
Gilbert ME, Mack CM. 1995. Seizure thresholds in kindled animals are reduced by the pesticides lindane and endosulfan. Neurotoxicol Teratol 17(2):143–150.7539098
Gilmore R, Sheets L, Hoss H. 2006. A developmental neurotoxicity study with technical grade endosulfan in Wistar rats. Project number: 201563, 05/D72/YF. Unpublished study prepared by Bayer Corp.
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Gorbach SG, Christ OE, Kellner H, . 1968. Metabolism of endosulfan in milk sheep. J Agric Food Chem 16:950–953.
Greve PA, Wit SL. 1971. Endosulfan in the Rhine River. J Water Pollut Control Fed 43:2338–2348.5118362
Griffith FD, Blanke RV. 1974. Microcoulometric determination of organochlorine pesticides in human blood. J Assoc Off Anal Chem 57:595–603.4833395
Guardino XC, Serra J, Obiols MG, . 1996. Determination of DDT and related compounds in blood samples from agricultural workers. J Chromatogr A 719(1):141–147.8589825
Guo H, Jin Y, Cheng Y, . 2014. Prenatal exposure to organochlorine pesticides and infant birth weight in China. Chemosphere 110:1–7. Nihms583119.24880592
Guo JY, Zeng EY, Wu FC, . 2007. Organochlorine pesticides in seafood products from southern China and health risk assessment. Environ Toxicol Chem 26(6):1109–1115.17571674
Gupta PK. 1976. Endosulfan-induced neurotoxicity in rats and mice. Bull Environ Contam Toxicol 15:708–713.938763
Gupta PK. 1978. Distribution of endosulfan in plasma and brain after repeated oral administration to rats. Toxicology 9:371–377.663945
Gupta PK, Chandra SV. 1975. The toxicity of endosulfan in rabbits. Bull Environ Contam Toxicol 14:513–519.1203562
Gupta PK, Chandra SV. 1977. Toxicity of endosulfan after repeated oral administration to rats. Bull Environ Contam Toxicol 18:378–384.907863
Gupta PK, Ehrnebo M. 1979. Pharmacokinetics of alpha isomer and beta isomers of racemic endosulfan following intravenous administration in rabbits. Drug Metab Dispos 7:7–10.35329
Gupta PK, Gupta RC. 1977a. Effect of endosulfan pretreatment on organ weights and on pentobarbital hypnosis in rats. Toxicology 7:283–288.888146
*Gupta PK, Gupta RC. 1977b. Influences of endosulfan on pentobarbitone sleeping time and blood and brain concentrations in male rats. J Pharm Pharmacol 29:245–246.17679
Gupta PK, Gupta RC. 1979. Pharmacology, toxicology and degradation of endosulfan. A review. Toxicology 13:115–130.390767
Gupta PK, Chandra SV, Saxena DK. 1978. Teratogenic and embryotoxic effects of endosulfan in rats. Acta Pharmacol Toxicol 42:150–152.
Gupta PK, Murthy RC, Chandra SV. 1981. Toxicity of endosulfan and manganese chloride: Cumulative toxicity rating. Toxicol Lett 7:221–227.7222097
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington DC: International Life Sciences Institute Press.
Hack R, Ebert E, Leist KH. 1995. Chronic toxicity and carcinogenicity studies with the insecticide endosulfan in rats and mice. Food Chem Toxicol 33(11):941–50.7590542
Hafner WD, Hites RA. 2003. Potential sources of pesticides, PCBs, and PAHs to the atmosphere of the Great Lakes. Environ Sci Technol 37(17):3764–3773.12967094
Hageman KJ, Hafner WD, Campbell DH, . 2010. Variability in pesticide deposition and source contributions to snowpack in western U.S. national parks. Environ Sci Technol 44(12):4452–4458.20499934
Hageman KJ, Simonich SL, Campbell DH, . 2006a. Atmospheric deposition of current-use and historic-use pesticides in snow at national parks in the western United States. Environ Sci Technol 40:3174–3180.16749678
Hageman KJ, Simonich SL, Campbell DH, . 2006b. Supporting information for: Atmospheric deposition of current-use and historic-use pesticides in snow at national parks in the western United States, S1–S10.
Hainzl D, Cole LM, Casida JE. 1998. Mechanisms for selective toxicity of Fipronil insecticide and its sulfone metabolite and desulfinyl photoproduct. Chem Res Toxicol 11(12):1529–1535.9860498
Halsall CJ, Barrie LA, Fellin P, . 1997. Spatial and temporal variation of polycyclic aromatic hydrocarbons in the arctic atmosphere. Environ Sci Technol 31(12):3593–3599.
Han EH, Hwang YP, Kim HG, . 2007. Inflammatory effect of endosulfan via NF-_κ_B activation in macrophages. Biochem Biophys Res Commun 355(4):860–865.17261270
Hansen DJ, Cripe GM. 1991. Interlaboratory comparison of the early life-stage toxicity test using sheepshead minnows (Cyprinodon variegatus). In: Mayes MA, Barron MG, eds. Aquatic toxicology and risk assessment. Vol. 14. Philadelphia, PA: American Society for Testing and Materials, 354–375.
Hapeman CJ, Schmidt WF, Rice CP, . 1997. Structural and thermodynamic considerations in the isomeric conversion of endosulfan. 213th National Meeting of the American Chemical Society, San Francisco, California, USA, April 13-17, 1997. Abstr Pap Am Chem Soc 213(1-3).
Harman-Fetcho JA, Hapeman CJ, McConnell LL, . 2005. Pesticide occurrence in selected south Florida canals and Biscayne Bay during high agricultural activity. J Agric Food Chem 53(15):6040–6048.16028993
Harner T, Shoeib M, Kozma M, . 2005. Hexachlorocyclohexanes and endosulfans in urban, rural, and high altitude air samples in the Fraser Valley, British Columbia: Evidence for trans-Pacific transport. Environ Sci Technol 39(3):724–731.15757332
Hatipoglu FS, Gulay MS, Balic A, . 2008. Subacute oral toxicity of endosulfan in male New Zealand white rabbits. Toxicol Mech Methods 18(9):705–710.20020928
Hayes WJ Jr. 1982. Pesticides studied in man. Baltimore, MD: Williams and Wilkins, 95, 252–253, 264.
HazDat. 2007. HazDat database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA. Agency for Toxic Substances and Disease Registry.
HCDB. 1986 Hazardous chemical data book. 2^nd^ Ed. Park Ridge, NJ. Noyes Data Corporation
Helaleh MIH, Al-Rashdan A. 2013. Automated pressurized liquid extraction (PLE) and automated power-prep® clean-up for the analysis of polycyclic aromatic hydrocarbons, organo-chlorinated pesticides and polychlorinated biphenyls in marine samples. Anal Methods 5:1617–1622.
Hinck JE, Blazer VS, Denslow ND, . 2007. Chemical contaminants, health indicators, and reproductive biomarker responses in fish from the Colorado River and its tributaries. Sci Total Environ 378(3):376–402.17418376
Hinck JE, Blazer VS, Denslow ND, . 2008. Chemical contaminants, health indicators, and reproductive biomarker responses in fish from rivers in the Southeastern United States. Sci Total Environ 390(2–3):538–557.18036634
Hiremath MB, Kaliwal BB. 2002a. The anti-implantation action of endosulfan in albino mice: Possible mechanisms. J Basic Clin Physiol Pharmacol 13(4):329–340.12751900
Hiremath MB, Kaliwal BB. 2002b. Effect of endosulfan on ovarian compensatory hypertrophy in hemicastrated albino mice. Reprod Toxicol 16(6):783–790.12401506
Hiremath MB, Kaliwal BB. 2003. Evaluation of estrogenic activity and effect of endosulfan on biochemical constituents in ovariectomized (OVX) Swiss albino mice. Bull Environ Contam Toxicol 71(3):458–464.14567570
Hodapp DM, Winterlin W. 1989. Pesticide degradation in model soil evaporation beds. Bull Environ Contam Toxicol 43:36–44.2758138
Hoechst. 1966a. Alpha-thiodan: Acute oral and subcutaneous toxicity to the mouse. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A14023. [unpublished study]
Hoechst. 1966b. Beta-thiodan: Acute oral and subcutaneous toxicity to the mouse. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A14024. [unpublished study]
Hoechst. 1970. Testing report on the toxicity of endosulfan (malix) to dogs through acute oral administration (LD50). Hoechst Aktiengesellschaft, Frankfurt, Germany. [unpublished study]
Hoechst. 1975. Beta-endosulfan pure (analysis GOE 1495): Acute oral toxicity in female SPF-Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A05270. [unpublished study]
Hoechst. 1982. Preliminary investigation of the effect of endosulfan (code, HOE 02671 OI AT 209) on reproduction of the rat. Hoechst Aktiengesellschaft, Frankfurt, Germany. Huntington Research Centre, Cambridgeshire, England. HST 203/82252. [unpublished study]
Hoechst. 1983a. Hoe 002671 - active ingredient technical: Testing for acute aerosol inhalation toxicity in male and female SPF Wistar rats: 4 Hours - LC50. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A28064. [unpublished study]
Hoechst. 1983b. Hoe 002671 - active ingredient technical: Test for sensitizing properties in female Pirbright-White guinea pigs according to the method of Buehler. Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. 83.0339. [unpublished study]
Hoechst. 1984a. Effect of endosulfan-technical (code HOE 02671 O I AT209) on reproductive function of multiple generations in the rat. Conducted for Hoechst Aktiengesellschaft, Frankfurt, Germany. Huntington Research Centre, Cambridgeshire, England. HST 204/83768. [unpublished study]
Hoechst. 1984b. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): 13-Weeks toxicity study in mice (final report). Conducted for Hoechst Aktiengesellschaft, Frankfurt, Germany. Huntington Research Centre, Cambridgeshire, England. HST 229/831052. [unpublished study]
Hoechst. 1984c. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): Testing for subchronic inhalation toxicity - 21 exposures in 29 days - in SPF Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A29766. [unpublished study]
Hoechst. 1984d. Evaluation of Hoe 002671 - substance technical - in the rat primary hepatocyte unscheduled DNA synthesis assay: Final report. Conducted for Hoechst Aktiengesellschaft, Frankfurt, Germany. Litton Bionetics, Inc., Kensington, MA. LBI project no. 10400-001. [unpublished study]
Hoechst. 1984e. Testing of the therapeutic effect of diazepam (Valium½) and phenobarbital (Luminal½) in the event of acute poisoning with endosulfan - active ingredient technical (code HOE 002671 OI ZD97 0003) in Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A28991. [unpublished study]
Hoechst. 1985a. Endosulfan-active ingredient technical (Code HOE 02671 OI ID970003) 13-week toxicity study in rats followed by a 4-week withdrawal period, conducted at Huntingdon Research Center, England. Hoechst Aktiengesellschaft, Frankfurt, West Germany. [unpublished study]
Hoechst. 1985b. Endosulfan - substance technical (code HOE 002671 OI ZD97 0003): 42-Day feeding study in mice. Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. A38104. [unpublished study]
Hoechst. 1985c. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): Testing for subchronic dermal toxicity - 21 applications over 30 days - in Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. 84.0223. [unpublished study]
Hoechst. 1985d. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): Testing for subchronic dermal toxicity - 21 applications over 30 days - in SPF Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Doc #A30751. [unpublished study]
Hoechst. 1986. A dermal absorption study in rats with 14C endosulfan: (Alternative version of study report MRID no. 40040701). Conducted for American Hoechst Corporation, Somerville, NJ. WIL Laboratories, Inc., Ashland, OH. Project no. WIL-39028. [unpublished study]
Hoechst. 1987. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): 30-Day feeding study in adult male Wistar rats. Hoechst Aktiengesellschaft, Frankfurt, Germany. Project no. 87.0129. [unpublished study]
Hoechst. 1988a. Beta-endosulfan (code HOE 052619 OI ZC99 0001): Testing for acute oral toxicity in the male and female Wistar rat. Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. 88.0822. [unpublished study]
Hoechst. 1988b. Endosulfan - active ingredient technical (code HOE 02671 OI ZD97 0003): Carcinogenicity study in mice: 24-Month feeding study. Hoechst Aktiengesellschaft, Frankfurt, Germany. TOXN no. 83.0113. [unpublished study]
Hoechst. 1988c. Endosulfan - substance technical (code HOE 02671 OI ZD96 0002): Testing of host resistance in the female Wistar rat (immunotoxicological screening with Trichinella spiralis). Hoechst Aktiengesellschaft, Frankfurt, Germany. Study no. 88.1419. [unpublished study]
Hoechst. 1988d. Evaluation of endosulfan - substance technical (code HOE 02671 OI ZD95 0005) in the unscheduled DNA synthesis test in mammalian cells in vitro. Hoechst Aktiengesellschaft, Frankfurt, Germany. Study no. 88.0106. [unpublished study]
Hoechst. 1989a. Endosulfan - substance technical (code HOE 02671 OI ZD97 0003): Combined chronic toxicity/carcinogenicity study: 104-Week feeding in rats. Conducted for Hoechst Aktiengesellschaft, Frankfurt, Germany. Huntington Research Centre, Cambridgeshire, England. Project no. HST 289/881067. [unpublished study]
Hoechst. 1989b. Endosulfan-beta - substance technical (code: HOE 052619 OI ZC99 0001): Preliminary cumulative dermal toxicity (5 treatments on 5 successive days) in the Wistar rat. Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. 89.0891. [unpublished study]
Hoechst. 1989c. Endosulfan - substance technical (code HOE 02671 OI ZD96 0002): Testing for toxicity by repeated oral administration (1-year feeding study) to Beagle dogs. Conducted for Hoechst Aktiengesellschaft, Frankfurt, Germany. Project no. 87.0643. [unpublished study]
Hoechst. 1990. Summary and evaluation of the toxicity data for endosulfan - substance technical. (code: HOE 002671) Hoechst Aktiengesellschaft, Frankfurt, Germany. Report no. 90.0848. [unpublished study]
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoh E, Hites RA. 2004. Sources of toxaphene and other organochlorine pesticides in North America as determined by air measurements and potential source contribution function analyses. Environ Sci Technol 38(15):4187–4194.15352459
HSDB. 1999. Endosulfan. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. February 7, 2000.
HSDB. 2009. Endosulfan sulfate. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 10, 2015.
HSDB. 2010. Endosulfan. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 10, 2015.
Hsu J-T, Ying C, Lan H-C. 1998. The effects of pesticides chlordane, dieldrin and endosulfan on the growth of human breast cancer cell lines MCF-7 and SK-BR-3. J Chinese Agric Chem Soc 36(6):535–546.
Hung H, Blanchard P, Halsall CJ, . 2005. Temporal and spatial variabilities of atmospheric polychlorinated biphenyl (PCBs), organochlorine (OC) pesticides and polycyclic aromatic hydrocarbons (PAHs) in the Canadian Arctic: Results from a decade of monitoring. Sci Total Environ 342:119–144.15866271
Hung H, Halsall CJ, Blanchard P, . 2002. Temporal trends of organochlorine pesticides in the Canadian arctic atmosphere. Environ Sci Technol 36(5):862–868.11918008
Hung H, Kallenborn R, Breivik K, . 2010. Atmospheric monitoring of organic pollutants in the Arctic under the Arctic Monitoring and Assessment Programme (AMAP): 1993-2006. Sci Total Environ 408(15):2854–2873.20004462
IARC. 2015. Agents classified by the IARC monographs. Volumes 1–112. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. March 31, 2015.
Indraningsih, McSweeney CS, Ladds PW. 1993. Residues of endosulfan in the tissues of lactating goats. Aust Vet J 70(2):59–62.8457174
*Innes JRM, Ulland BM, Valerio MG, . 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: A preliminary note. J Natl Cancer Inst 42:1101–1114.5793189
IRIS. 2002. Endosulfan (CASRN 115-29-7). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0235.htm March 31, 2015.
Jain N, Srivastava P, Joshi SC. 2013. Testicular dysfunction in male rat following endosulfan exposure. Int J Pharmaceut Sci Rev Res 21:108–113.
Jaiswal A, Parihar VK, Sudheer Kumar M, . 2005. 5-Aminosalicylic acid reverses endosulfan-induced testicular toxicity in male rats. Mutat Res 585(1–2):50–59.16002328
Jalili S, Farshid AA, Heydari R, . 2007. Histopathological observations on protective effects of vitamin E on endosulfan induced cardiotoxicity in rats. Pakistan J Biol Sci 10(11):1922–1925.
Jamil K, Shaik AP, Mahboob M, . 2004. Effect of organophosphorus and organochlorine pesticides (monochrotophos, chlorpyriphos, dimethoate, and endosulfan) on human lymphocytes in-vitro. Drug Chem Toxicol 27(2):133–144.15198073
Jindal A, Sankhyan N. 2012. Endosulfan poisoning resulting from skin exposure. Indian J Pediatr 79(8):1104.22161579
Jonsson CM, Toledo MC. 1993. Bioaccumulation and elimination of endosulfan in the fish yellow tetra (Hyphessobyrcon bifasciatus). Bull Environ Contam Toxicol 50:572–577.8467144
Kalender S, Kalender Y, Ogutcu A, . 2004a. Endosulfan-induced cardiotoxicity and free radical metabolism in rats: The protective effect of vitamin E. Toxicology 202(3):227–235.15337585
Kalender Y, Kalender S, Uzunhisarcikli M, . 2004b. Effects of endosulfan on B cells of Langerhans islets in rat pancreas. Toxicology 200(2–3):205–211.15212816
Kamate M, Jain A. 2011. Accidental endosulfan ingestion in a toddler. Indian J Pediatr 78(7):884–885.21267795
Kannan K, Jain SK. 2003. Oxygen radical generation and endosulfan toxicity in Jurkat T-cells. Mol Cell Biochem 247(1–2):1–7.12841624
Karatas AD, Aygun D, Baydin A. 2006. Characteristics of endosulfan poisoning: A study of 23 cases. Singapore Med J 47(12):1030–1032.17139397
Kathpal TS, Singh A, Dhankhar JS, . 1997. Fate of endosulfan in cotton soil under sub-tropical conditions in Northern India. Pestic Sci 50:21–27.
Kaur I, Kumar A, Duraja P. 1997. Separation of endosulphan and its major metabolites by GC and HPLC. Biomed Chromatogr 11:33–35.9051214
Kaur I, Mathur RP, Tandon SN, . 1998. Persistence of endosulfan (technical) in water and soil. Environmental Technology 19(1):115–119.
Kazen C, Bloomer A, Welch R, . 1974. Persistence of pesticides on the hands of some occupationally exposed people. Arch Environ Health 29:315–318.4279630
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092.13679531
Kelly BC, Ikonomou MG, Blair JD, . 2007. Food web-specific biomagnification of persistent organic pollutants. Science 317(5835):236–239.17626882
Khan PK, Sinha SP. 1996. Ameliorating effect of vitamin C on murine sperm toxicity induced by three pesticides (endosulfan, phosphamidon and mancozeb). Mutagenesis 11(1):33–36.8671712
Khanna RN, Misra D, Anand M, . 1979. Distribution of endosulfan in cat brain. Bull Environ Contam Toxicol 22:72–79.465792
Kiran R, Varma MN. 1988. Biochemical studies on endosulfan toxicity in different age groups of rats. Toxicol Lett 44:247–252.2851197
Kolpin DW, Blazer VS, Gray JL, . 2013. Chemical contaminants in water and sediment near fish nesting sites in the Potomac River basin: Determining potential exposures to smallmouth bass (Micropterus dolomieu). Sci Total Environ 443:700–716.23228716
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Kovalkovicova N, Sutiakova I, Kacmar P, . 2001. Chromosomal aberrations induced by the insecticide endosulfan in sheep peripheral lymphocytes in vitro. Acta Vet (Beogr) 51(5–6):365–372.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuang Z, McConnell LL, Torrents A, . 2003. Atmospheric deposition of pesticides to an agricultural watershed of the Chesapeake Bay. J Environ Qual 32(5):1611–1622.14535301
Kumar SN, Telang AG, Singh KP, . 2011. Experimentally induced toxicity of ochratoxin A and endosulfan in male Wistar rats: A hormonal disorder. J Anim Vet Adv 10(13):1750–1755.
Kurinnyi AI, Pilinskaya MA, German IV, . 1982. Implementation of a program of cytogenetic study of pesticides: Preliminary evaluation of cytogenetic activity and potential mutagenic hazard of 24 pesticides. Tsitol Genet 16:50–53.
Lafuente A, Pereiro N. 2013. Neurotoxic effects induced by endosulfan exposure during pregnancy and lactation in female and male rat striatum. Toxicology 311(1–2):35–40.23702353
Lakshmana MK, Raju TR. 1994. Endosulfan induces small but significant changes in the levels of noradrenaline, dopamine and serotonin in the developing rat brain and deficits in the operant learning performance. Toxicology 91(2):139–50.8059438
Lebailly P, Vigreux C, Lechevrel C, . 1998. DNA damage in mononuclear leukocytes of farmers measured using the alkaline comet assay: Modifications of DNA damage levels after a one-day field spraying period with selected pesticides. Cancer Epidemiol Biomarkers Prev 7:929–940.9796639
Lee HK, Moon JK, Chang CH, . 2006. Stereoselective metabolism of endosulfan by human liver microsomes and human cytochrome P450 isoforms. Drug Metab Dispos 34(7):1090–1095.16581944
Lee N, Beasley HL, Kimber S WL, . 1997a. Application of immunoassays to studies of the environmental fate of endosulfan. J Agric Food Chem 45(10):4147–4155.
Lee N, Beasley HL, Silburn M, . 1997b. Validation and application of immunoassays to studies of the environmental fate of endosulfan. In: Abstracts of Papers: Part 1: 213 ACS National Meeting. American Chemical Society, San Francisco, CA, April 13–17, 1997. Washington, DC: American Chemical Society, Abstract 117.
Lee S, McLaughlin R, Harnly M, . 2002. Community exposures to airborne agricultural pesticides in California: Ranking of inhalation risks. Environ Health Perspect 110(12):1175–1184.12460795
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Legler J, van den Brink CE, Brouwer A, . 1999. Development of a stably transfected estrogen receptor-mediated luciferase reporter gene assay in the human T47D breast cancer cell line. Toxicol Sci 48:55–66.10330684
Leung HW. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
Li Y, Luh CJ, Burns KA, . 2013. Endocrine-disrupting chemicals (EDCs): In vitro mechanism of estrogenic activation and differential effects on ER target genes. Environ Health Perspect 121(4):459–466.23384675
Lindquist DA, Dahm PA. 1957. Some chemical and biological experiments with Thiodan. J Econ Entomol 50:483–486.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lo RSK, Chan JC, Cockram CS, . 1995. Acute tubular necrosis following endosulphan insecticide poisoning. J Toxicol Clin Toxicol 33(1):67–69.7837316
Lozowicka B. 2013. The development, validation and application of a GC-dual detector (NPD-ECD) multi-pesticide residue method for monitoring bee poisoning incidents. Ecotoxicol Environ Saf 97:210–222.23916014
Lu Y, Morimoto K, Takeshita T, . 2000. Genotoxic effects of α-endosulfan and β-endosulfan on human HepG2 cells. Environ Health Perspect 108(6):559–561.10856031
Lutter C, Iyengar V, Barnes R, . 1998. Breast milk contamination in Kazakhstan: Implications for infant feeding. Chemosphere 37(9–12):1761–1772.9828304
L’Vova TS. 1984. [Study of the mutagenic effect of 5 promising pesticides in mouse bone marrow cultured human peripheral blood lymphocytes, and in the yeast Saccharomyces cerevisiae.] Tsitol Genet 18:455–457. (Russian)6395457
MacKenzie KM, Felton SM, Dickie SM, . 1981. Raltech Study No. 80070. Teratology study with FMC 5462 in rabbits. FMC Corporation. Submitted to U.S. Environmental Protection Agency. MRID504800201.
Mahran KMA. 2013. Clinicopathological studies on endosulfan-induced oxidative stress and the protective role of vitamin E. Global Veterinaria II 11(2):258–265.
Maier-Bode H. 1968. Properties, effect, residues and analytics of the insecticide endosulfan. Residue Rev 22:1–44.4868139
Manjula SD, Benjamin S, Bairy KL. 2006. Modulatory effect of vitamin C on genotoxic effect of endosulfan in developing albino rats. Iranian J Pharmacol Ther 5(2):113–116.
Mansour S, Mohamed D, Gamet-Payrastre L. 2014. Effects of indirect exposure of mice pups to endosulfan via their dams during gestation and lactation periods and the ameliorative effect of vitamin E. Hum Exp Toxicol 33(9):911–927.24299906
Mariani G, Benfenati E, Fanelli R. 1995. A NICI-GC-MS method to analyze endosulfan in biological samples. Int J Environ Anal Chem 58(1–4):67–72.
Mariscal-Arcas M, Lopez-Martinez C, Granada A, . 2010. Organochlorine pesticides in umbilical cord blood serum of women from southern Spain and adherence to the Mediterranean diet. Food Chem Toxicol 48(5):1311–1315.20188779
Martens R. 1976. Degradation of [8,9,-14C] endosulfan by soil microorganisms. Appl Environ Microbiol 31:853–858.7195
Martens R. 1977. Degradation of endosulfan (−8,9-14C) in soil under different conditions. Bull Environ Contam Toxicol 17:438–446.861397
Mast MA, Alvarez DA, Zaugg SD. 2012a. Deposition and accumulation of airborne organic contaminants in Yosemite National Park, California. Environ Toxicol Chem 31(3):524–533.22189687
Mast MA, Alvarez DA, Zaugg SD. 2012b. Supplemental data: Desposition and accumulation of airborne organic contaminants in Yosemite National Park, California, 2008-09.1-37. http://onlinelibrary.wiley.com/store/10.1002/etc.1727/asset/supinfo/etc_1727_sm_SupplData.doc?v=1&s=16c62d30472d159eac9ef918c6c0dceb321dc63f. June 21, 2012.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk*/tk- mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12:85–154.3383842
Meister RT, Sine C, Melnick R, . 2011. Endosulfan. In: Meister RT, Sine C, Melnick R, . eds. Crop protection handbook 2011. Willoughby OH: Meister Media Worldwide, 384–385.
Metcalf RL. 1995. Insect control technology. In: Kirk-Othmer’s encyclopedia of chemical technology. 4^th^ Ed. New York, NY: John Wiley & Sons, 524–602.
Miles AK, Ricca MA, Anthony RG, . 2009. Organochlorine contaminants in fishes from coastal waters west of Amukta Pass, Aleutian Islands, Alaska, USA. Environ Toxicol Chem 28(8):1643–1654.19374473
Miles JRW, Moy P. 1979. Degradation of endosulfan and its metabolites by a mixed culture of soil microorganisms. Bull Environ Contam Toxicol 23:13–19.497418
Milesi MM, Varayoud J, Bosquiazzo VL, . 2012. Neonatal exposure to low doses of endosulfan disrupts the expression of proteins regulating uterine development and differentiation. Reprod Toxicol 33(1):85–93.22198180
*Misra D, Khanna RN, Anand M, . 1982. Interaction of endosulfan with erythrocyte membrane. J Adv Zool 3:135–141.
Misra R, Srivastava N, Misra UK, . 1980. Effect of endosulphan on aniline hydroxylase activity of hepatic SER in rats fed lysine, threonine deficient and supplemented rice diets. Nutr Rep Int 21:425–428.
Montgomery JH. 1993. Agrochemicals desk reference- environmental data. Boca Raton, FL: Lewis Publishers, 192–193.
Moon JM, Chun BJ. 2009. Acute endosulfan poisoning: A retrospective study. Hum Exp Toxicol 28(5):309–316.19755461
Mor F, Ozmen O. 2010. Effect of vitamin C in reducing the toxicity of endosulfan in liver in rabbits. Exp Toxicol Pathol 62(1):75–80.19285844
Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5(6):485–527.
Moses V, Peter JV. 2010. Acute intentional toxicity: Endosulfan and other organochlorines. Clin Toxicol (Phila) 48(6):539–544.20572757
Muller F, Streibert HP, Farooq M. 2009. Acaricides. In: Ullmann’s encyclopedia of industrial chemistry. Vol. 1. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co., 91–190.
Nagda G, Bano H, Bhatt DK. 2011. Protective effect of vitamin E on endosulfan induced testicular toxicity in Swiss mice (Mus musculus). J Exp Sci 2(6):29–34.
*Narayan S, Bajpai A, Chauhan SS, . 1985a. Lipid peroxidation in lung and liver of rats given DDT and endosulfan intratracheally. Bull Environ Contam Toxicol 34:63–67.3971060
*Narayan S, Bajpai A, Tyagi SR, . 1985b. Effect of intratracheal administration of DDT and endosulfan on cytochrome P-450 and glutathione-s-transferase in lung and liver of rats. Bull Environ Contam Toxicol 34:55–62.3971059
*Narayan S, Dani HM, Misra UK. 1984. Effect of intratracheally administered DDT and endosulfan on pulmonary and hepatic respiratory cytochromes. Bull Environ Contam Toxicol 33:193–199.6466900
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nath G, Dikshith TSS. 1979. Endosulfan residues in rat tissues. Natl Acad Sci Lett 2:278–279.
Nath G, Datta KK, Dikshith TSS, . 1978. Interaction of endosulfan and metepa in rats. Toxicology 11:385–393.749275
NCI. 1968. Evaluation of carcinogenic, teratogenic and mutagenic activities of selected pesticides and industrial chemicals. Volume I: Carcinogenic study. Prepared by Bionetics Research Labs, Inc., Bethesda, MD: National Cancer Institute. NCI-DCCP-CG-1973-1-1.
NCI. 1978. Bioassay of endosulfan for possible carcinogenicity. Carcinogenesis Testing Program, NCI Technical Report Series No. 62, DHEW Publication no. NIH 78-1312. Bethesda, MD: National Cancer Institute. NCI-CG-TR-62.
Nicholson SS, Cooper GW. 1977. Apparent endosulfan toxicosis in calves [clinical item]. J Am Vet Med Assoc 130:319.
NIOSH. 1984. National occupational exposure survey (1980-1983). U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH. October 18, 1989.
NIOSH. 1992. NIOSH recommendations for Occupational Safety and Health. Compendium of Policy Documents and Statements. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control. National Institute for Occupational Safety and Health. Publication no. 92-100. Cincinnati, Ohio.
NIOSH. 1995. Report to Congress on Workers’ Home Contamination Study conducted under the workers’ family protection act (29 U.S.C.671a). U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health. September 1995.
NIOSH. 2011. Endosulfan. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 25, 2012.
NIOSH. 2015. Endosulfan. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgd0251.html. March 4, 2015.
NOAA. 2012. NCCOS NS&T data portal. National Oceanic and Atmospheric Administration. http://egisws02.nos.noaa.gov/nsandt/index.html#. May 9, 2012.
NPIRS. 2012. Pesticide products. National Pesticide Information Retrieval System. http://ppis.ceris.purdue.edu/htbin/ppisprod.com. May 9, 2012.
NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
NRCC. 1975. Endosulfan: Its effects on environmental quality. Ottawa, Ontario: National Research Council Canada, Environmental Secretariat. Publication no. NRCC 14098.
NTP. 2014. Report on carcinogens, Thirteenth Edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Services, National Toxicology Program. http://ntp.niehs.nih.gov/pubhealth/roc/roc13/. March 31, 2015.
OHM/TADS. 1989. Oil and Hazardous Materials/Technical Assistance Data System. Chemical Information Systems. September 14, 1989.
Olea N, Olea-Serrano F, Lardelli-Claret P, . 1999. Inadvertent exposure to xenoestrogens in children. Toxicol Ind Health 15(1–2):151–158.10188197
Omurtag GZ, Tozan A, Sehirli AO, . 2008. Melatonin protects against endosulfan-induced oxidative tissue damage in rats. J Pineal Res 44(4):432–438.18205731
O’Neil M, Heckelman PE, Koch CB, . 2006. Endosulfan. In: O’Neil M, Heckelman PE, Koch CB, . eds. The Merck index. Whitehouse Station NJ: Merck & Co., Inc., 509.
OSHA. 1989. Air Contaminants. Occupational Safety and Health Administration. Fed Regist. 54 FR 2608. Final Rule. January 19, 1989.
OSHA. 1993. Air Contaminants. Occupational Safety and Health Administration. U.S. Department of Labor. Fed Regist. 58 FR 35338. Final Rule. June 30, 1993.
OSHA. 2013. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910-1000.pdf. March 4, 2015.
OSHA. 2014a. Gases, vapors, fumes, dusts, and mists. Appendix A to 1926.55-1970. American Conference of Governmental Industrial Hygienists’ threshold limit values of airborne contaminants for construction. Subpart D-Occupational health and environmental controls. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol8/pdf/CFR-2014-title29-vol8-sec1926-55.pdf. March 4, 2015.
OSHA. 2014b. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol7/pdf/CFR-2013-title29-vol7-sec1915-1000.pdf. March 4, 2015.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ozdem S, Nacitarhan C, Gulay MS, . 2011. The effect of ascorbic acid supplementation on endosulfan toxicity in rabbits. Toxicol Ind Health 27(5):437–446.21245203
Ozmen O, Mor F. 2012. Apoptosis in adult rabbit testes during subacute endosulfan toxicity. Pestic Biochem Physiol 102(2):129–133.
Ozmen O, Sahinduran S, Mor F. 2010. Pathological and immunohistochemical examinations of the pancreas in subacute endosulfan toxicity in rabbits. Pancreas 39(3):367–370.19959968
Ozoe Y, Matsumura F. 1986. Structural requirements for bridged bicyclic compounds acting on picrotoxinin receptor. J Agric Food Chem 34:126–134.
Pal R, Ahmed T, Kumar V, . 2009. Protective effects of different antioxidants against endosulfaninduced oxidative stress and immunotoxicity in albino rats. Indian J Exp Biol 47(9):723–729.19957884
Parbhu B, Rodgers G, Sullivan JE. 2009. Death in a toddler following endosulfan ingestion. Clin Toxicol (Phila) 47(9):899–901.19852624
Paul V, Balasubramaniam E, Jayakumar AR, . 1995. A sex-related difference in the neurobehavioral and hepatic effects following chronic endosulfan treatment in rats. Eur J Pharmacol 293(4):355–360.8748688
Paul V, Balasubramaniam E, Kazi M. 1994. The neurobehavioural toxicity of endosulfan in rats: A serotonergic involvement in learning impairment. Eur J Pharmacol 270(1):1–7.8157075
Pednekar MD, Gandhi SR, Netrawali MS. 1987. Evaluation of mutagenic activities of endosulfan, phosalone, malathion, and permethrin, before and after metabolic activation, in the Ames salmonella test. Bull Environ Contam Toxicol 38:925–933.3555658
Pennington PL, DeLorenzo ME, Lawton JC, . 2004. Modular estuarine mecocosm validation: Ecotoxicological assessment of direct effects with the model compound endosulfan. J Exp Mar Biol Ecol 298:369–387.
Perobelli JE, Martinez MF, da Silva Franchi CA, . 2010. Decreased sperm motility in rats orally exposed to single or mixed pesticides. J Toxicol Environ Health A 73(13–14):991–1002.20563933
Pfeuffer RJ. 2011. South Florida water management district ambient pesticide monitoring network: 1992 to 2007. Environ Monit Assess 182(1–4):485–508.21340551
Phang W. 1990. Memorandum: Endosulfan: Review of four toxicology studies and three dermal absorption studies. Submitted to the U.S. Environmental Protection Agency. MRID Tox Review 007937. http://www.epa.gov/pesticides/chemical/foia/cleared-reviews/reviews/079401/079401-105.pdf. June 21, 2012.
Pomes A, Rodriguez-Farre E, Sunol C. 1994. Disruption of GABA-dependent chloride flux by cyclodienes and hexachlorocyclohexanes in primary cultures of cortical neurons. J Pharmacol Exp Ther 271(3):1616–1623.7996476
Popov VB, Protasova GA, Radilov AS. 1998. Embryo-and genotoxic effects of two endosulfan forms in the culture of rat and mouse pre- and postimplantation embryos. Ontogenez 29(2):104–112.9608956
Pozo K, Harner T, Wania F, . 2006. Toward a global network for persistent organic pollutants in air: Results from the GAPS study. Environ Sci Technol 40(16):4867–4873.16955879
Pradhan S, Pandey N, Phadke RV, . 1997. Selective involvement of basal ganglia and occipital cortex in a patient with acute endosulfan poisoning. J Neurol Sci 147(2):209–213.9106131
Raizada RB, Srivastava MK, Dikshith TSS. 1991. Lack of estrogenic effects of endosulfan: An organochlorine insecticide in rat. Nat Acad Sci Lett 14(2):103–107.
Rajendran N, Venogopalan VK. 1991. Bioconcentration of endosulfan in different body tissues of estuarine organisms under sublethal exposure. Bull Environ Contam Toxicol 46:151–158.2001486
Ramamoorthy K, Wang F, Chen I-C, . 1997. Estrogenic activity of a dieldrin/toxaphene mixture in the mouse uterus, MCF-7 human breast cancer cells, and yeast-based estrogen receptor assays: No apparent synergism. Endocrinology 138(4):1520–1527.9075711
Rao M, Narayana K, Benjamin S, . 2005. L-ascorbic acid ameliorates postnatal endosulfan induced testicular damage in rats. Indian J Physiol Pharmacol 49(3):331–336.16440852
Ratra GS, Kamita SG, Casida JE. 2001. Role of human GABA(A) receptor beta3 subunit in insecticide toxicity. Toxicol Appl Pharmacol 172(3):233–240.11312652
Rau A, Coutinho A, Avabratha KS, . 2012. Pesticide (endosulfan) levels in the bone marrow of children with hematological malignancies. Indian Pediatr 49(2):113–117.21992855
*Razi-Ul-Hussnain R, Khalil-ur-Rehman, Sheikh M A, . 1995. Effect of oral administration of endosulfan on the haematochemical parameters of rabbits. Pak Vet J 15(2):81–84.
Ren A, Qiu X, Jin L, . 2011. Association of selected persistent organic pollutants in the placenta with the risk of neural tube defects. Proc Natl Acad Sci USA 108(31):12770–12775.21768370
RePORTER. 2012. Endosulfan. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm June 20, 2012.
Reuber MD. 1981. The role of toxicity in the carcinogenicity of endosulfan. Sci Total Environ 20:23–47.7280658
Rice CP, Chernyak SM, Hapeman CJ, . 1997. Air-water distribution of the endosulfan isomers. J Environ Qual 26:1101–1106.
Rice CP, Nochetto CB, Zara P. 2002. Volatilization of trifluralin, atrazine, metolachlor, chlorpyrifos, α-endosulfan, and β-endosulfan from freshly tilled soil. J Agric Food Chem 50(14):4009–4017.12083875
Riederer AM, Smith KD, Barr DB, . 2010. Current and historically used pesticides in residential soil from 11 homes in Atlanta, Georgia, USA. Arch Environ Contam Toxicol 58(4):908–917.20016886
Roberts D. 1972. The assimilation and chronic effects of sub-lethal concentrations of endosulfan on condition and spawning in the common mussel Mylitus edulis. Mar Biol 16:119–125.
Roberts DM, Dissanayake W, Rezvi Sheriff MH, . 2004. Refractory status epilepticus following self-poisoning with the organochlorine pesticide endosulfan. J Clin Neurosci 11(7):760–762.15337143
Roberts EM, English PB, Grether JK, . 2007. Maternal residence near agricultural pesticide applications and autism spectrum disorders among children in the California Central Valley. Environ Health Perspect 115(10):1482–1489.17938740
Rosa R, Rodriguez-Farre E, Sanfeliu C. 1996. Cytotoxicity of hexachlorocyclohexane isomers and cyclodienes in primary cultures of cerebellar granule cells. J Pharmacol Exp Ther 278(1):163–169.8764347
Rousseau J, Cossette L, Grenier S, . 2002. Modulation of prolactin expression by xenoestrogens. Gen Comp Endocrinol 126:175–182.12030773
RTECS. 2012. 5-Norbornene-2,3-dimethanol, 1,4,5,6,7,7-hexachloro-, cyclic sulfite. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. March 8, 2012.
Rudel H. 1997. Volatilisation of pesticides from soil and plant surfaces. Chemosphere 35(1–2):143–152.
Saiyed H, Dewan A, Bhatnagar V, . 2003. Effect of endosulfan on male reproductive development. Environ Health Perspect 111(16):1958–1962.14644673
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286.10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3:Article 46.10.3389/fphar.2012.00046.
Scarpato R, Hirvonen A, Migliore L, . 1997. Influence of GSTMI and GSTTI polymorphisms on the frequency of chromosome aberrations in lymphocytes of smokers and pesticide-exposed greenhouse workers. Mutat Res 389:227–235.9093388
Scarpato R, Migliore L, Angotzi G, . 1996a. Cytogenic monitoring of a group of Italian floriculturists: No evidence of DNA damage related to pesticide exposure. Mutat Res 367:73–82.8643118
Scarpato R, Migliore L, Hirvonen A, . 1996b. Cytogenetic monitoring of occupational exposure to pesticides: Characterization of GSTM1, GSTT1, and NAT2 genotypes. Environ Mol Mutagen 27:263–269.8665871
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schimmel SC, Patrick JM Jr, Wilson AJ Jr. 1977. Acute toxicity to and bioconcentration of endosulfan by estuarine animals. In: Mayer FL, Hamelink JL, eds. Aquatic toxicology and hazard evaluation ASTM STP 634. Philadelphia, PA: American Society for Testing and Materials, 241–252.
Schuman SH, Dobson RL. 1985. An outbreak of contact dermatitis in farm workers. J Am Acad Dermatol 13:220–223.2931456
Scippo ML, Argiris C, Van De Weerdt C, . 2004. Recombinant human estrogen, androgen and progesterone receptors for detection of potential endocrine disruptors. Anal Bioanal Chem 378(3):664–669.14579009
Scott GI, Fulton MH, Wirth EF, . 2002. Toxicological studies in tropical ecosystems: An ecotoxicological risk assessment of pesticide runoff in south Florida estuarine ecosystems. J Agric Food Chem 50(15):4400–4408.12105977
Seth PK, Saidi NF, Agrawal AK, . 1986. Neurotoxicity of endosulfan in young and adult rats. Neurotoxicology 7:623–635.3024081
Shah ASV, Eddleston M. 2010. Should phenytoin or barbiturates be used as second-line anticonvulsant therapy for toxicological seizures? Clin Toxicol (Phila) 48(8):800–805.20923393
Sheets L, Gilmore R, Fickbohm B. 2004. A subchronic neurotoxicity screening study with technical grade endosulfan in Wistar rats. Project Number: 02/N72/MJ, 201069. Unpublished study prepared by Bayer Corp.
Shelby MD, Newbold RR, Tully DB, . 1996. Assessing environmental chemicals for estrogenicity using a combination of in vitro and in vivo assays. Environ Health Perspect 104(12):1296–1300.9118870
Shemesh Y, Bourvine A, Gold D, . 1988. Survival after acute endosulfan intoxication. J Toxicol Clin Toxicol 26:265–268.3418779
Shen H, Main KM, Virtanen HE, . 2007. From mother to child: Investigation of prenatal and postnatal exposure to persistent bioaccumulating toxicants using breast milk and placenta biomonitoring. Chemosphere 67(9):S256–S262.17207515
Shen L, Wania F, Lei YD, . 2005. Atmospheric distribution and long-range transport behavior of organochlorine pesticides in North America. Environ Sci Technol 39(2):409–420.15707039
Siddharth M, Datta SK, Bansal S, . 2012. Study on organochlorine pesticide levels in chronic kidney disease patients: Association with estimated glomerular filtration rate and oxidative stress. J Biochem Mol Toxicol 26(6):241–247.22645066
Siddiqui MKJ, Anjum F, Qadri SSH. 1987a. Some metabolic changes induced by endosulfan in hepatic and extra hepatic tissues of rat. J Environ Sci Health B22:553–564.
Siddiqui MKJ, Rahman MF, Anjum F, . 1987b. Effect of oral administration of endosulfan on some hematological parameters and serum enzymes in rats. Pesticides 21:25–27.
Silva MH, Carr WC, Jr. 2010. Human health risk assessment of endosulfan: II. Dietary exposure assessment. Regul Toxicol Pharmacol 56(1):18–27.19733202
Silva de Assis HC, Nicaretta L, Marques MC, . 2011. Anticholinesterasic activity of endosulfan in Wistar rats. Bull Environ Contam Toxicol 86(4):368–372.21340455
Singh N, Chhillar N, Banerjee B, . 2013. Organochlorine pesticide levels and risk of Alzheimer’s disease in north Indian population. Hum Exp Toxicol 32(1):24–30.22899726
Singh ND, Sharma AK, Dwivedi P, . 2007b. Citrinin and endosulfan induced maternal toxicity in pregnant Wistar rats: Pathomorphological study. J Appl Toxicol 27(6):589–601.17429798
Singh ND, Sharma AK, Dwivedi P, . 2007a. Citrinin and endosulfan induced teratogenic effects in Wistar rats. J Appl Toxicol 27(2):143–151.17186572
Singh ND, Sharma AK, Dwivedi P, . 2008. Experimentally induced citrinin and endosulfan toxicity in pregnant Wistar rats: Histopathological alterations in liver and kidneys of fetuses. J Appl Toxicol 28(7):901–907.18493935
Singh SK, Pandey RS. 1989. Gonadal toxicity of short term chronic endosulfan exposure to male rats. Indian J Exp Biol 27:341–346.2553591
Singh SK, Pandey RS. 1990. Effect of sub-chronic endosulfan exposures on plasma gonadotrophins, testosterone, testicular testosterone and enzymes of androgen biosynthesis in rat. Indian J Exp Biol 28:953–956.2279768
Singh N, Singh CP, Kumar H, . 1992. Endosulfan poisoning: A study of 22 cases. J Assoc Physicians India 40(2):87–88.1629143
Sinha N, Adhikari N, Saxena DK. 2001. Effect of endosulfan during fetal gonadal differentiation on spermatogenesis in rats. Environ Toxicol Pharmacol 10(1–2):29–32.11382554
Sinha N, Narayan R, Saxena DK. 1997. Effect of endosulfan on the testis of growing rats. Bull Environ Contam Toxicol 58(1):79–86.8952929
Sinha N, Narayan R, Shanker R, . 1995. Endosulfan-induced biochemical changes in the testis of rats. Vet Hum Toxicol 37(6):547–549.8588293
Sobti RC, Krishan A, Davies J. 1983. Cytokinetic and cytogenetic effect of agricultural chemicals on human lymphoid cells in vitro: II. Organochlorine pesticides. Arch Toxicol 52:221–231.6860144
Soto AM, Chung KL, Sonnenschein C. 1994. The pesticides endosulfan, toxaphene, and dieldrin have estrogenic effects on human estrogen-sensitive cells. Environ Health Perspect 102(4):380–383.7925178
Soto AM, Sonnenschein C, Chung KL, . 1995. The E-SCREEN assay as a tool to identify estrogens: An update on estrogenic environmental pollutants. Environ Health Perspect Suppl 103(7):113–122.
Sparling DW, Fellers GM, McConnell LL. 2001. Pesticides and amphibian population declines in California, USA. Environ Toxicol Chem 20(7):1591–1595.11434303
Sriram K, Misra UK. 1983. Interaction of endosulfan and dietary vitamin A on rat hepatic drug metabolizing enzymes. Acta Vitaminol Enzymol 5:213–218.6424426
Stern GA, Macdonald CR, Armstrong D, . 2005. Spatial trends and factors affecting variation of organochlorine contaminants levels in Canadian Arctic beluga (Delphinapterus leucas). Sci Total Environ 352:344–368.
Stewart DKR, Cairns KG. 1974. Endosulfan persistence in soil and uptake by potato tubers. J Agric Food Chem 22:984–986.4430810
Strandberg B, Hites RA. 2001. Concentration of organochlorine pesticides in wine corks. Chemosphere 44(4):729–735.11482662
Sun P, Backus S, Blanchard P, . 2006. Temporal and spatial trends of organochlorine pesticides in Great Lakes precipitation. Environ Sci Technol 40(7):2135–2141.16646444
Terziev G, Dimitrova N, Rusev F. 1974. Forensic medical and forensic chemical study of acute lethal poisinnins with thiodan. Folia Med 16:325–329.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton NJ: Princeton Scientific Publishing, 365–394.
Toledo MCF, Jonsson CM. 1992. Bioaccumulation and elimination of endosulfan in zebra fish (Brachydanio rerio). Pestic Sci 36:207–211.
Tomlin C, ed. 2003. Endosulfan (294) e-Pesticide manual. 13th ed. United Kingdom: British Crop Protection Council.
Tyagi SR, Singh Y, Srivastava PK, . 1984. Induction of hepatic mixed function oxidase system by endosulfan in rats. Bull Environ Contam Toxicol 32:550–556.6733301
Umar H, Ali E, Daniel E, . 2012. Endosulfan-induced changes in sperm count, testicular weight and some erythrocyte indices in male guinea pigs. Br J Pharmacol Toxicol 3(4):151–155.
USDA. 2012. Pesticide data program. Annual summary, calendar year 2010. Washington, DC: U.S. Department of Agriculture, Agricultural Marketing Service, Science and Technology Programs.
USGS. 2012a. 2002 Pesticide use maps. Endosulfan-insecticide. U.S. Geological Survey. http://water.usgs.gov/nawqa/pnsp/usage/maps/show_map.php?year=02&map=m6019. May 9, 2012.
USGS. 2012b. NAWQA queries: Groundwater. U.S. Geological Survey. http://infotrek.er.usgs.gov/nawqa_queries/jsp/gwmaster.jsp. March 19, 2012.
USGS. 2012c. NAWQA queries: Surface water/bed sediment. U.S. Geological Survey. http://infotrek.er.usgs.gov/nawqa_queries/jsp/swmaster.jsp. March 19, 2012.
Usha Rani MV, Reddy PP. 1986. Cytogenetic effects of aldrin and endosulfan in mice. IRCS J Med Sci 14:1125–1126.
Usha Rani MV, Reddi OS, Reddy PP. 1980. Mutagenicity studies involving aldrin, endosulfan, dimethoate, phosphamidon, carbaryl and ceresan. Bull Environ Contam Toxicol 25:277–282.6775717
Valdez-Marquez M, Lares ML, Camacho Ibar V, . 2004. Chlorinated hydrocarbons in skin and blubber of two blue whales (Balaenoptera musculus) stranded along the Baja California coast. Bull Environ Contam Toxicol 72(3):490–495.15114447
Vale C, Fonfria E, Bujons J, . 2003. The organochlorine pesticides γ-hexachlorocyclohexane (lindane), α-endosulfan and dieldrin differentially interact with GABA(A) and glycine-gated chloride channels in primary cultures of cerebellar granule cells. Neuroscience 117(2):397–403.12614680
Vanparys C, Maras M, Lenjou M, . 2006. Flow cytometric cell cycle analysis allows for rapid screening of estrogenicity in MCF-7 breast cancer cells. Toxicology in vitro: an international journal published in association with BIBRA 20(7):1238–1248.16797915
Varayoud J, Monje L, Bernhardt T, . 2008. Endosulfan modulates estrogen-dependent genes like a non-uterotrophic dose of 17 β-estradiol. Reprod Toxicol 26(2):138–145.18790044
Velazquez A, Creus A, Xamena N, . 1984. Mutagenicity of the insecticide endosulfan in Drosophila melanogaster. Mutat Res 136:115–118.6425685
Venegas W, Zapata I, Carbonell E, . 1998. Micronuclei analysis in lymphocytes of pesticide sprayers from Conception, Chile. Teratog Carcinog Mutagen 18:123–129.9728796
Verschueren K. 1977. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, Inc., 40–42, 604–607.
Verschueren K. 2001. Endosulfan. In: Handbook of environmental data on organic chemicals. 4th ed. New York, NY: John Wiley & Sons, Inc., 1041–1044.
Vidal JLM, Arrebola FJ, Fernandez-Gutierrez A, . 1998. Determination of endosulfan and its metabolites in human urine using gas chromatography-tandem mass spectrometry. J Chromatogr 719:71–78.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vonier PM, Crain DA, McLachlan JA, . 1996. Interaction of environmental chemicals with the estrogen and progesterone receptors from the oviduct of the American alligator. Environ Health Perspect 104(12):1318–1322.9118873
Vos JG, Krajnc EI, Beekhof PK, . 1982. Methods for testing immune effects of toxic chemicals: Evaluation of the immunotoxicity of various pesticides in the rat. In: Miyamoto J, Kearney PC, eds. Pesticide chemistry: Human welfare and the environment. Oxford England: Pergamon Press, 497–504.
Wade MG, Desaulniers D, Leingartner K, . 1997. Interactions between endosulfan and dieldrin on estrogen-mediated processes in vitro and in vivo. Reprod Toxicol 11(6):791–798.9407589
Wang N, Qian HY, Zhou XQ, . 2012. Mitochondrial energy metabolism dysfunction involved in reproductive toxicity of mice caused by endosulfan and protective effects of vitamin E. Ecotoxicol Environ Saf 82:96–103.22705290
Wang N, Xu Y, Zhou XQ, . 2014. Protective effects of testosterone propionate on reproductive toxicity caused by endosulfan in male mice. Environ Toxicol [Epub Ahead of Print].
Wania F, Shen L, Lei Y, . 2003. Development and calibration of a resin-based passive sampling system for monitoring persistent organic pollutants in the atmosphere. Environ Sci Technol 37(7):1352–1359.
Weber J, Halsall CJ, Muir D, . 2010. Endosulfan, a global pesticide: A review of its fate in the environment and occurrence in the Arctic. Sci Total Environ 408:2966–2984.19939436
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Weston DP, You J, Lydy MJ. 2004. Distribution and toxicity of sediment-associated pesticides in agriculture-dominated water bodies of California’s Central Valley. Environ Sci Technol 38(10):2752–2759.15212247
White-Stevens R, ed. 1971. Pesticides in the environment. Vol. 1, part 1, part 2, New York, NY: Marcel Dekker, Inc., 89, 140, 214–216, 227–236.
WHO. 1984. Endosulfan. International Programme on Chemical Safety. Environmental Health Criteria 40. Geneva, Switzerland: World Health Organization, 1–62.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
Wilson VS, LeBlanc GA. 1998. Endosulfan elevates testosterone biotransformation and clearance in CD-1 mice. Toxicol Appl Pharmacol 148(1):158–168.9465275
Wilson WW, Onyenwe W, Bradner JM, . 2014a. Developmental exposure to the organochlorine insecticide endosulfan alters expression of proteins associated with neurotransmission in the frontal cortex. Synapse 68(11):485–497.25042905
Wilson WW, Shapiro LP, Bradner JM, . 2014b. Developmental exposure to the organochlorine insecticide endosulfan damages the nigrostriatal dopamine system in male offspring. Neurotoxicology 44:279–287. Nihms618606.25092410
Working PK. 1988. Male reproductive toxicology: Comparison of the human to animal models. Environ Health Perspect 77:37–44.3289906
Yadav AS, Vashishat RK, Kakar SN. 1982. Testing of endosulfan and fenitrothion for genotoxicity in Saccharomyces cerevisiae. Mutat Res 105:403–407.6759933
Yaduvanshi SK, Srivastava N, Marotta F, . 2012. Evaluation of micronuclei induction capacity and mutagenicity of organochlorine and organophosphate pesticides. Drug Metab Lett 6(3):187–197.23092307
*Yaqoob H, Ilahi A, Iqbal T, . 1995. Effect of oral administration of endosulfan on the haematoenzymic parameters of rabbits. Pak Vet J 15(2):61–64.
Yavuz Y, Yurumez Y, Kucuker H, . 2007. Two cases of acute endosulfan toxicity. Clin Toxicol (Phila) 45(5):530–532.17503261
Zaidi NF, Agrawal AK, Anand M, . 1985. Neonatal endosulfan neurotoxicity: Behavioral and biochemical changes in rat pups. Neurobehav Toxicol Teratol 7:439–442.4080062
Zervos IA, Nikolaidis E, Lavrentiadou SN, . 2011. Endosulfan-induced lipid peroxidation in rat brain and its effect on t-PA and PAI-1: Ameliorating effect of vitamins C and E. J Toxicol Sci 36(4):423–433.21804306
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372