# PEER REVIEW

A peer review panel was assembled for endosulfan. The panel consisted of the following members:

1. Marilyn H. Silva, Ph.D. DABT, Department of Pesticide Regulation, Medical Toxicology Branch, Sacramento, California;
2. M. Eddleston MA, Ph.D., FRCP Edin, Scottish Senior Clinical Research Fellow, Clinical Pharmacology Unit, University of Edinburgh, Consultant Clinical Toxicologist and Director, National Poisons Information Service - Edinburgh, Royal Infirmary, Visiting Professor, University of Copenhagen, Department of International Health, Immunology and Microbiology, Edinburgh, Scotland;
3. Mark Gregory Robson, Ph.D., MPH, DrPH (hc), Dean of Agricultural and Urban Programs, Professor of Entomology, School of Environmental and Biological Sciences, Rutgers University, New Brunswick, New Jersey.

These experts collectively have knowledge of endosulfan’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.