# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration oral MRL of 0.007 mg/kg/day for endosulfan based on a NOAEL of 0.7 mg/kg/day for neurological signs in rabbits (MacKenzie et al. 1981). The MRL was derived by dividing the NOAEL of 0.7 mg/kg/day by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

ATSDR has derived an intermediate-duration oral MRL of 0.005 mg/kg/day for endosulfan based on a NOAEL of 0.45 mg/kg/day for immunological effects in rats (Banerjee and Hussain 1986). The MRL was derived by dividing the NOAEL of 0.45 mg/kg/day by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

ATSDR has adopted the intermediate-duration oral MRL for endosulfan for the chronic-duration oral MRL.

The EPA (IRIS 2002) has derived an oral reference dose (RfD) of 0.006 mg/kg/day for endosulfan based on a NOAEL of 0.6 mg/kg/day for reduced body weight gain in male and female rats and increased incidence of marked progressive glomerulonephrosis and blood vessel aneurysms in male rats in a 2-year feeding study. An uncertainty factor of 100 was used (10 for intraspecies variability and 10 for interspecies extrapolation). No reference concentration (RfC) for chronic inhalation exposures to endosulfan was reported. EPA’s Office of Chemical Safety and Pollution Prevention (EPA 2010b) derived a chronic population-adjusted dose (cPAD) of 0.006 mg/kg/day based on the same data from which EPA’s RfD was derived.

The EPA, the International Agency for Research on Cancer (IARC), and the National Toxicology Program (NTP) have not classified endosulfan as to its carcinogenicity (IARC 2015; IRIS 2002; NTP 2014). The American Conference of Governmental Industrial Hygienists (ACGIH) has classified endosulfan as an A4 carcinogen (not classifiable as a human carcinogen) (ACGIH 2014).

Endosulfan, endosulfan sulfate, α-endosulfan, and β-endosulfan have been designated as a hazardous substances pursuant to the Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) of 1980 (EPA 201d). The statutory source for this designation for endosulfan sulfate, α-, and β-isomers is Section 307 of the Clean Water Act (CWA). In addition to Section 307(a) of the CWA, the designation for endosulfan is based on Section 311(b)(2) of the CWA, and Section 3001 of the Resource Conservation and Recovery Act (RCRA) (EPA 2014d). The owner and operator of any facility that produces, uses, or stores a CERCLA hazardous substance in an amount exceeding the “threshold planning quantity” are required to immediately report any release to any environmental media, if the amount released is equal to or exceeds the specified “reportable quantity” assigned to the substance. As a hazardous substance that is formulated as a solid, endosulfan is subject to either of two threshold planning quantities (EPA 2013d). If a solid hazardous substance exits in powdered form and has a particle size less than 100 micrometers, then it is subject to the lower number. If the solid does not meet this criterion, then it is subject to the higher number. The threshold reporting quantities for endosulfan are 10 and 10,000 pounds (EPA 2013d). The reportable quantity for endosulfan and its metabolites is 1 pound (EPA 2013d).

Endosulfan is designated as a hazardous substance under Section 311 of the CWA; any discharge of these chemicals over a specified threshold level (10 pounds) into navigable waters is subject to reporting requirements (EPA 2013c).

Between June 27, 1974 and January 18, 1989, the Occupational Safety and Health Administration (OSHA) had promulgated protective, permissible exposure limits (PELs) for approximately 264 toxic substances (OSHA 1993). The OSHA PELs were established to protect workers against adverse health effects resulting from exposure to hazardous substances. The PELs determined for hazardous substances are enforceable, regulatory limits on allowable indoor air concentrations. OSHA requires employers of workers who are occupationally exposed to these hazardous air contaminants to institute engineering controls and work practices to reduce and maintain employee exposure at or below PELs. An employer must ensure that an employee’s exposure in any 8-hour work shift of a 40-hour week does not exceed the 8-hour time-weighted average (TWA) established for the air contaminant (OSHA 2013). On January 18, 1989, OSHA promulgated more protective PELs for approximately 376 toxic substances. Endosulfan was included among 164 toxic substances not previously regulated (OSHA 1989). The newly established PEL for endosulfan was set at 0.1 mg/m^3^ (OSHA 1989). OSHA also provided a “skin designation” for endosulfan. Because the 1989 promulgation was rescinded by the 11th Circuit Court Appeals in July 1992, only those PELs in place prior to the 1989 rule are currently enforced by OSHA. On June 30, 1993, OSHA published in the Federal Register a final rule announcing the revocation of the 1989 exposure limits, including the newly established limits for endosulfan (OSHA 1993). Currently, there is no OSHA PEL for endosulfan. However, the National Institute for Occupational Safety and Health (NIOSH) and several states adopted the 0.1 mg/m^3^ exposure limit for endosulfan that was initially promulgated by OSHA (NIOSH 1992, 2015).

The international and national regulations, advisories, and guidelines regarding endosulfan in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Endosulfan

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2015
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | | WHO 2011
WHO | Endosulfan | No data^a^
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2014
ACGIH | Endosulfan^b,c^ | 0.1 mg/m^3^
AIHA | ERPGs | No data | AIHA 2014
DOE | PAC-1^d^ | | DOE 2012a
DOE | Endosulfan | 0.1 mg/m^3^
DOE | PAC-2^d^
DOE | Endosulfan | 0.8 mg/m^3^
DOE | PAC-3^d^
DOE | Endosulfan | 280 mg/m^3^
EPA | AEGLs | No data | EPA 2014a
EPA | NAAQS | No data | EPA 2012h
NIOSH | REL (10-hour TWA) | | NIOSH 2015
NIOSH | Endosulfan^e^ | 0.1 mg/m^3^
NIOSH | IDLH
NIOSH | Endosulfan | No data
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013 29 CFR 1910.1000, Table Z-1
OSHA | PEL (8-hour TWA) for construction Endosulfan^e^ | 0.1 mg/m^3^ | OSHA 2014a 29 CFR 1916.55, Appendix A
OSHA | PEL (8-hour TWA) for shipyards Endosulfan^e^ | 0.1 mg/m^3^ | OSHA 2014b 29 CFR 1915.1000
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | | EPA 2013a 40 CFR 116.4
EPA | Endosulfan | Yes
EPA | Drinking water standards and health advisories | No data | EPA 2012g
EPA | Master Testing List | No data | EPA 2014b
EPA | National primary drinking water standards | No data | EPA 2009
EPA | National recommended water quality criteria: freshwater and saltwater | | EPA 2013b
EPA | α-Endosulfan and β-endosulfan
EPA | Freshwater CMC (acute)^f,g^ | 0.22 μg/L
EPA | Freshwater CCC (chronic)^f,g^ | 0.056 μg/L
EPA | Saltwater CMC (acute)^f,g^ | 0.034 μg/L
EPA | Saltwater CCC (chronic)^f,g^ | 0.0087 μg/L
EPA | National recommended water quality criteria: human health for the consumption
EPA | Endosulfan sulfate, α-endosulfan, and β-endosulfan
EPA | Water plus organism^h^ | 62 μg/L
EPA | Organism only^h^ | 89 μg/L
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2013c 40 CFR 117.3
EPA | Endosulfan | 1 pound
c. Food
FDA | EAFUS^i^ | No data | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2014
ACGIH | Endosulfan | A4^j^
EPA | Carcinogenicity classification | No data | IRIS 2002
EPA | RfC | No data
EPA | RfD
EPA | Endosulfan | 0.006 mg/kg/day
EPA | Inert pesticide ingredients in pesticide products | No data | EPA 2014c
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity | | EPA 2014d 40 CFR 302.4
EPA | Endosulfan^k^ | 1 pound
EPA | Endosulfan sulfate^l^ | 1 pound
EPA | α-Endosulfan^l^ | 1 pound
EPA | β-Endosulfan^l^ | 1 pound
EPA | Effective date of toxic chemical release reporting | No data | EPA 2014e 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity Endosulfan | | EPA 2013d 40 CFR 355, Appendix A
EPA | Reportable quantity | 1 pound
EPA | Threshold planning quantity | 10/10,000 pounds
NTP | Carcinogenicity classification | No data | NTP 2014

a Endosulfan occurs in drinking-water at concentrations well below those at which toxic effects may occur.

b Inhalable fraction and vapor is noted because endosulfan exerts sufficient vapor pressure such that it may be present in both particle and vapor phases, with each contributing a significant portion of the dose at the TLV-TWA concentration.

c Skin: refers to the potential significant contribution to the overall exposure by the cutaneous route.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2012b).

e Skin designation

f The CMC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed briefly without resulting in an unacceptable effect. The CCC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed indefinitely without resulting in an unacceptable effect. The CMC and CCC are just two of the six parts of an aquatic life criterion; the other four parts are the acute averaging period, chronic averaging period, acute frequency of allowed exceedance, and chronic frequency of allowed exceedance. Because 304(a) aquatic life criteria are national guidance, they are intended to be protective of the vast majority of the aquatic communities in the United States.

g This value was derived from data for endosulfan and is most appropriately applied to the sum of α-endosulfan and β-endosulfan.

h This criterion has been revised to reflect The EPA’s q_1_* or RfD, as contained in IRIS as of May 17, 2002.

i The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

j A4: not classifiable as a human carcinogen

k Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and Section 307(a)of the Clean Water Act and Section 3001 of RCRA.

l Designated CERCLA hazardous substance pursuant to Section 307(a)of the Clean Water Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CCC = criterion continuous concentration; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CMC = criteria maximum concentration; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization