# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Technical-grade endosulfan contains at least 94% of two pure isomers, α- and β-endosulfan. The α- and β-isomers of endosulfan are present in the ratio of 7:3, respectively (FAO 2011a; Müller et al. 2009). Endosulfan sulfate is a reaction product found in technical endosulfan; it is also found in the environment due to oxidation by biotransformation (Dureja and Mukerjee 1982). The chemical formula, structure, synonyms, and identification numbers for endosulfan, α-endosulfan, β-endosulfan, and endosulfan sulfate are listed in Tables 4-1, 4-2, 4-3, and 4-4, respectively.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Important physical and chemical properties of endosulfan, α-endosulfan, β-endosulfan, and endosulfan sulfate are listed in Tables 4-5, 4-6, 4-7, and 4-8, respectively. It should be noted that β-endosulfan is slowly converted to α-endosulfan (Hapeman et al. 1997; Rice et al. 1997).

Table 4-1 Chemical Identity of Endosulfan

Characteristic | Information^a^
Chemical name | Endosulfan
Synonym(s) | 6,7,8,9,10,10-Hexachloro-1,5,5a,6,9,9a-hexahydro-6,9-methano-2,4,3-benzodioxathiepin-3-oxide; Endosulfan technical; 5-Norbornene-2,3-dimethanol-1,4,5,6,7,7-hexachlorocyclic sulfit
Registered trade name(s) | Thiodan; Thionex; Thionate Malix; HOE 2671; FMC 5462; Cyclodan; Thifor; Beosit; Chlorthiepin; Endosulphan^b^
Chemical formula | C_9_H_6_Cl_6_O_3_S^c^
Chemical structure^e^ | [image]
Identification numbers:
CAS registry | 115-29-7^c^
NIOSH RTECS | RB9275000^c^
EPA hazardous waste | P050
OHM/TADS | 7216559
DOT/UN/NA/IMDG shipping | 2761^c^
HSDB | 390
NCI | C00566

a All information obtained from HSDB 2010, except where noted.

b HSDB 2010; O’Neil et al. 2006

c NIOSH 2015

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Chemical Identity of α-Endosulfan

Characteristic | Information
Chemical name | α-Endosulfan^a^
Synonym(s) | Endosulfan I; Endosulfan A; 6,9-Methano-2,4,3-benzodioxathiepin, 6,7,8,9,10,10-hexachloro-1,5,5a,6,9,9a-hexahydro-, 3-oxide (3α, 5a β, 6α, 9a α, 9β)-; 5-Norbornene-2,3-dimethanol, 1,4,5,6,7,7-hexachloro-, cyclic sulfite, endo-^b^
Registered trade name(s) | α-Benzoepin; α-Thiodan; β-Thionex^c^
Chemical formula | C_9_H_6_Cl_6_O_3_S^b^
Chemical structure^e^ | [image]
Identification numbers:
CAS registry | 959-98-8^a^
NIOSH RTECS | RB9275100^c^
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | No data
HSDB | No data
NCI | No data

a Tomlin 2003

b RTECS 2012; Tomlin 2003

c RTECS 2012

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-3 Chemical Identity of β-Endosulfan

Characteristic | Information
Chemical name | β-Endosulfan^a^
Synonym(s) | Endosulfan II; Endosulfan B; 6,7,9,10,10-Hexachloro-1,5,5a,6,9,9a-hexahydro-6,9-methano-2,4,3-benzodiozathiepin-3-oxide, (3α, 5aα, 6β, 9β, 9aα-; 5-Norbornene-2,3-dimethanol, 1,4,5,6,7,7-hexachloro-, cyclic sulfite, endo-^b^
Registered trade name(s) | β-Benzoepin; β-Thiodan; α -Thionex^c^
Chemical formula | C_9_H_6_Cl_6_O_3_S^b^
Chemical structure^e^ | [image]
Identification numbers:
CAS registry | 33213-65-9^a^
NIOSH RTECS | RB9875200^c^
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | No data
HSDB | No data
NCI | No data

a Tomlin 2003

b RTECS 2012; Tomlin 2003

c RTECS 2012

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-4 Chemical Identity of Endosulfan Sulfate

Characteristic | Information
Chemical name | Endosulfan sulfate^a^
Synonym(s) | 6,7,8,9,10,10-Hexachloro-1,5,5a,6,9,9a-hexahydro-6,9-methano-2,4,3-benzodiozathiepin-3,3-dioxide; 5-Norbornene-2,3-dimethanol, 1,4,5,6,7,7-hexachloro-, cyclic Sulfate^a,b^
Registered trade name(s) | No data
Chemical formula | C_9_H_6_Cl_6_O_4_S^a^
Chemical structure^b^ | [image]
Identification numbers:
CAS registry | 1031-07-8^a^
NIOSH RTECS | RB9150000^b^
EPA hazardous waste | No data
OHM/TADS | 8300205^c^
DOT/UN/NA/IMDG shipping | No data
HSDB | 6180^a^
NCI | No data

a HSDB 2009

b RTECS 2012

c OHM/TADS 1989

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-5 Physical and Chemical Properties of Endosulfan

Property | Information | Reference
Molecular weight | 406.93 | O’Neil et al. 2006
Color | Cream to brown; mostly beige | Tomlin 2003
Physical state | Crystalline solid; waxy solid (commercial product) | NIOSH 2011; O’Neil et al. 2006
Melting point:
Pure | 106 °C | O’Neil et al. 2006
Technical | 70–100 °C | O’Neil et al. 2006
Boiling point | 106 °C | HSDB 2010
Density at 20/4 °C | 1.745 g/mL | HSDB 2010
Density for vapor | 14 | HCDB 1986
Odor:
α-Endosulfan | Terpene-like; Slight, sulfur dioxide odor | HSDB 2010
Decomposition products | May have a slight odor of sulfur dioxide | HSDB 2010
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25 °C | 0.53 mg/L | HSDB 2010
Organic solvents at 20 °C:
Dichloromethane | 200 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Ethanol | 65 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Ethyl acetate | 200 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Hexane | 24 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Toluene | 200 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Acetone | 262 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Benzene | 333 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Carbon tetrachloride | 460 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Chloroform | 746 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Ethanol | 40 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Kerosene | 164 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Methanol | 89 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Xylene | 388 g/L | Coleman and Dolinger 1982; HSDB 2010; Maier-Bode 1968
Partition coefficients:
Log K_ow_ | 3.83 (alpha) and 3.62 (beta) | HSDB 2010
Log K_oc_ | 4.03 (alpha) and 4.13 (beta) | EPA 2010a
Vapor pressure at 25 ° C | 1×10^−5^ mmHg | Coleman and Dolinger 1982; EPA 1982
Vapor pressure at 25 °C | 1.73×10^−7^ | HSDB 2010
Vapor pressure at 880 °C | 9×10^−3^ mmHg | Maier-Bode 1968; NRCC 1975
Henry’s law constant at 20 °C | 6.5×10^−5^ atm m^3^/mol | HSDB 2010
Autoignition temperature | No data
Flashpoint | No data
Flammability limits in air | No data
Reactivity | Both isomers are slowly hydrolyzed by aqueous acids and alkalis, with the formation of the diol and sulfur dioxide | Tomlin 2003
Reactivity | α and β isomers are rapidly oxidized by peroxides or permanganate to endosulfan sulfate | HSDB 2010
Reactivity | The β form is slowly converted to the more stable a form at high temperatures | Hapeman et al. 1997; Rice et al. 1997
Reactivity | Both isomers slowly oxidize in air to endosulfan sulfate | Metcalf 1995
Reactivity | Corrosive to iron | O’Neil et al. 2006
Reactivity | Hydrolyzed rapidly by alkalies | O’Neil et al. 2006
Conversion factors:
ppm (v/v) to mg/m^3^ in air at 25 °C | 1 ppm=0.0601 mg/m^3^ | Verschueren 1977
mg/m^3^ to ppm (v/v) in air at 25 °C | 1 mg/m^3^=16.64 ppm | Verschueren 1977
Explosive limits | No data

Table 4-6 Physical and Chemical Properties of α-Endosulfan

Property | Information | Reference
Molecular weight | 406.93 | O’Neil et al. 2006
Color:
Pure | Colorless | HSDB 2010
Technical | Cream to brown, mostly beige | Tomlin 2003
Physical state | Crystalline solid | HSDB 2010
Melting point | 108–110 °C | O’Neil et al. 2006
Boiling point | No data
Density at 20/4 °C | No data
Density for vapor
Odor: | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 22 °C (pH 7.2) | 0.15 mg/L | HSDB 2010
Water at 25 °C | 0.53 mg/L | HSDB 2010
Organic solvents at 20 °C | No data
Partition coefficients:
Log K_ow_ | 3.83 | HSDB 2010
Log K_oc_ | 3.55 | HSDB 1999
Vapor pressure at 25 °C | 1×10^−5^ mmHg | EPA 1982
Henry’s law constant at 25 °C | 1×10^−5^ atm m^3^/mol | EPA 1982
Henry’s law constant at 25 °C | 1.01×10^−4^ atm m^3^/mol | Montgomery 1993
Autoignition temperature | No data
Flashpoint | No data
Flammability limits in air | No data
Conversion factors:
ppm (v/v) to mg/m^3^ in air at 25 °C | 1 ppm=0.0601 mg/m^3^ | Verschueren 1977
mg/m^3^ to ppm (v/v) in air at 25 °C | 1 mg/m^3^=16.64 ppm | Verschueren 1977
Explosive limits | No data

Table 4-7 Physical and Chemical Properties of β-Endosulfan

Property | Information | Reference
Molecular weight | 406.93 | O’Neil et al. 2006
Color | Cream or tan | Tomlin 2003
Physical state | Crystalline solid | Budavari 1996
Melting point | 208–210 °C | O’Neil et al. 2006
Boiling point | No data
Density at 20/4 °C | No data
Density for vapor
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 22 °C (pH 7.2) | 0.33 | HSDB 2010
Water at 25 °C | 0.28 | HSDB 2010
Organic solvents at 20 °C | Soluble in most organic solvents | O’Neil et al. 2006
Partition coefficients:
Log K_ow_ | 3.62 | HSDB 2010
Log K_oc_ | 4.1 | Verschueren 2001
Vapor pressure at 25 °C | 1×10^−5^ mmHg | EPA 1982
Henry’s law constant at 25 °C | 1.91×10^−5^ atm m^3^/mol | EPA 1982
Autoignition temperature | No data
Flashpoint | No data
Flammability limits in air | No data
Reactivity | Both isomers are slowly hydrolysed by aqueous acids and alkalis, with the formation of the diol and sulfur dioxide | Tomlin 2003
Reactivity | The β form is slowly converted to the more stable α form at high temperatures | Hapeman et al. 1997; Rice et al. 1997
Conversion factors:
ppm (v/v) to mg/m^3^ in air at 25 °C | 1 ppm=0.0601 mg/m^3^ | Verschueren 1977
mg/m^3^ to ppm (v/v) in air at 25 °C | 1 mg/m^3^=16.64 ppm | Verschueren 1977
Explosive limits | No data

Table 4-8 Physical and Chemical Properties of Endosulfan Sulfate

Property | Information | Reference
Molecular weight | 422.95 | HSDB 2009
Color | Brown | HSDB 2009
Physical state | Crystalline solid | HSDB 2009
Melting point | 181–182 °C; 198–201 °C | EPA 1982; HSDB 2012; White-Stevens 1971
Boiling point | No data
Density at 20/4 °C | No data
Density for vapor
Odor | Pungent | HSDB 2009
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 22 °C (pH 7.2) | 0.22 | EPA 1982; NRCC 1975; OHM/TADS 1989
Water at 25 °C | 0.117; 0.22 | EPA 1982; NRCC 1975; OHM/TADS 1989
Organic solvents at 20 °C | No data | EPA 1982; NRCC 1975; OHM/TADS 1989
Partition coefficients:
Log K_ow_ | 3.66 | EPA 1979
Log K_oc_ | No data
Vapor pressure at 25 °C | 1.0×10^−11^ mmHg | HSDB 2009
Henry’s law constant at 25 °C | 2.61×10^−5^ atm m^3^/mol | EPA 1982
Autoignition temperature | No data
Flashpoint | No data
Flammability limits in air | No data
Conversion factors:
ppm (v/v) to mg/m^3^ in air at 25 °C | 1 ppm=0.058 mg/m^3^ | Verschueren 1977
mg/m^3^ to ppm (v/v) in air at 25 °C | 1 mg/m^3^=17.29 ppm | Verschueren 1977
Explosive limits | No data