# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Endosulfan Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endosulfan
CAS Numbers: | 115-29-7
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 32
Species: | Rabbit

[underlined: Minimal Risk Level]: 0.007 [X] mg/kg/day [ ] ppm

[underlined: Reference]: MacKenzie KM, Felton SM, Dickie SM, . 1981. Raltech Study No. 80070. Teratology study with FMC 5462 in rabbits. FMC Corporation . Submitted to U.S. Environmental Protection Agency. MRID504800201.

[underlined: Experimental design]: Groups of mated New Zealand White rabbits (20/ dose group) were administered technical endosulfan by gavage in corn oil in doses of 0, 0.3, 0.7, or 1.8 mg/kg/day from GD 6 to 28; dams were sacrificed on GD 29. Body weight was measured on GD 0 and 6 and at 6-day intervals thereafter. Body weight was also measured on sacrifice day (actual and corrected for gravid uterine weight). Clinical signs were monitored twice daily. At necropsy, the ovaries were removed and examined for gross abnormalities and the number of corpora lutea was recorded. The gravid uterus was weighed and opened after external examination. The following parameters were recorded: number and location of live and dead fetuses, early and late resorptions, empty sites and implantation scars, unusual coloration and variation in amniotic fluid and placenta, and any other abnormalities. Fetuses, were sexed, measured, weighed, examined grossly, and given a thorough visceral examination and then prepared for skeletal examination.

[underlined: Effect noted in study and corresponding doses]: Since deaths occurred in the high-dose group (not totally clear when these deaths occurred), 6 mated females were added to this group for a total of 26 dams. It appears that after the six dams were added to the high-dose group, four dams died before the study termination, three of them possibly due to regurgitation and aspiration of the test material into the trachea and lung and the fourth of unestablished causes. No deaths occurred in the other groups. Neurological signs were observed in three high-dose dams within 4 days of the start of treatment (in one female on GD 6, the day of the first dose, and in two females on GD 10, after four doses). The signs consisted of noisy and rapid breathing, hyperactivity and convulsions. No such signs occurred in the other treated groups or in the control group. No rabbits aborted during this study. Treatment with endosulfan did not significantly affect body weight changes between GD 0 and 29 (corrected or uncorrected). Exposure to endosulfan did not significantly alter pregnancy maintenance, implantation, litter size, sex ratio, mean fetal weight and length, or number and percent of live or resorbed fetuses. There were no dead fetuses in any treatment group or in controls. Exposure to endosulfan also did not result in dose-related increased incidences of gross, soft tissue, or skeletal malformations.

As indicated in Section 2.3, although the incidence of neurological effects of 3/26 reported in the high-dose group within 4 days after dosing started is not statistically different from 0/20 in the other groups (p=0.1713, Fisher Exact Test), it is appropriate to consider the 1.8 mg/kg/day dose level a LOAEL based on the biological significance of the effect. Therefore, the dose level of 1.8 mg/kg/day in the MacKenzie et al. (1981) study is considered an acute LOAEL for neurological signs; the NOAEL is 0.7 mg/kg/day.

Incidence data for neurological signs in rabbits occurring within 14 days after dosing started in the MacKenzie et al. (1981) study were analyzed using the BMD approach. The incidence data were 0/20, 0/20, 0/20, and 3/26 in the control, 0.3, 0.7, and 1.8 mg/kg/day dose groups, respectively. Models in the EPA BMDS (version 2.1.1) were fit to the data set to determine potential PODs for the MRL. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest benchmark dose (BMDL, the lower limit of a one-sided 95% confidence interval on the BMD) is selected as the POD when differences between the BMDLs estimated from these models are >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s information criterion (AIC) is chosen. In accordance with EPA (2000a) guidance, BMDs and BMDLs associated with an extra risk of 10% are calculated for all models. For continuous data such as changes in body weight, in the absence of a clear criteria as to what level of change in body/organ weight or body weight gain should be considered adverse, the BMR is defined as a change in weight or weight/gain equal to 1 standard deviation from the control mean (EPA 2000a). Using the criteria for model selection mentioned above, the Gamma model (BMD_10_ 1.76 mg/kg/day; BMDL_10_ 1.23 mg/kg/day) was selected as the best model to fit the incidence of clinical signs in pregnant female rabbits. However, the BMDL_10_ of 1.23 mg/kg/day is not only very close to the BMD_10_ of 1.76 mg/kg/day, a dose that caused serious effects in the study, but it is even closer to a dose of 1.5 mg/kg/day, which caused the same type of serious clinical signs and even death in one of nine rabbits in the Hatipoglu et al. (2008) study. Taking this into consideration and in the interest of protecting human health, the NOAEL of 0.7 mg/kg/day for clinical signs in the MacKenzie et al. (1981) study is preferred as the POD for derivation of an acute-duration oral MRL for endosulfan.

[underlined: Dose and end point used for MRL derivation]: 0.7 mg/kg/day; neurological clinical signs.

[ X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Neurological effects are characteristic of endosulfan and other chlorinated pesticides in humans and animals. An additional study in rabbits reported clinical signs including hyperexcitability, dyspnea, hyperpnea, intermittent intervals of tremors and tonic-clonic convulsions, thrashing against the cage walls, depression, and forelimb extension leading to death in 1/9 and 2/9 New Zealand White male rabbits 10–40 minutes following gavage dosing with 1.5 or 3 mg/kg endosulfan, respectively (Hatipoglu et al. 2008).

[underlined: Agency Contact (Chemical Manager)]: Jessilynn Taylor

## Endosulfan Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endosulfan
CAS Numbers: | 115-29-7
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 73
Species: | Rat

[underlined: Minimal Risk Level]: 0.005 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Banerjee BD, Hussain QZ. 1986. Effect of sub-chronic endosulfan exposure on humoral and cell-mediated immune responses in albino rats. Arch Toxicol 59:279–284 3827596 .

[underlined: Experimental design]: Groups of male Wistar (10–12/group) (85–90 g body weight) received technical-grade endosulfan (α- and β-endosulfan in the ratio of 7:3) in their diets at dietary levels of 0, 5, 10, or 20 ppm (equivalent to 0, 0.45, 0.9, and 1.8 mg/kg/day, using the EPA [1988] food factor for male Wistar rats, subchronic duration). Test diets were prepared by dissolving the endosulfan in groundnut oil and mixing this into standard laboratory diet. Samples analyzed from each batch of diet indicated that the actual levels of endosulfan in the diet were within 10% of the desired levels. Control animals received a diet with an equal amount of groundnut oil mixed in. Rats were randomly allocated to groups and were caged four to a stainless steel, mesh-bottom cage. Food and water were available to these rats on “as needed” basis for between 8 and 22 weeks. At weeks 8, 12, 18, and 22, between 10 and 12 rats were selected from each group and sacrificed. Twenty days before sacrifice, the rats were immunized by injecting 0.2 mL of tetanus toxin mixed with an equal volume of Freund’s adjuvant subcutaneously. An additional group of 10–12 rats per dose was sacrificed at the time periods indicated, but these rats were not immunized with the tetanus toxin and adjuvant. At the time of sacrifice, the liver, spleen, and thymus were removed and weighed, blood samples were collected by cardiac puncture, and peritoneal exudate was collected by washing the peritoneal cavity with between 10 and 15 mL of RMPI medium.

The antibody titer to tetanus toxin was estimated using an indirect hemagglutination technique. Briefly, a suspension of sheep red blood cells was treated with tannic acid (1:20,000 dilution) and used for antigen coating. Tetanus toxin was then mixed with the treated sheep red blood cell and antibody titers were determined using the first dilution where no visible agglutination was observed. Serum proteins were determined using zone electrophoresis. Quantitation of serum levels of IgG and IgM was performed using radial immunodiffusion in agarose containing either anti IgG or anti IgM. The leukocyte migration inhibition test was performed using leukocytes isolated from rat blood by sequential centrifugation and washing. Migration from micro capillary tubes was measured using a camera lucida and migration into control medium was compared with migration into medium containing tetanus toxin. The macrophage migration inhibition test was performed using microphages isolated from the peritoneal exudate by sequential centrifugation and washing. Migration was measured as described above for the leukocytes.

[underlined: Effect noted in study and corresponding doses]: No difference between the controls and rats given diets containing 5 ppm endosulfan was observed in any of the parameters measured. Rats consuming diets containing 10 ppm endosulfan and treated with tetanus toxin had significantly decreased serum IgG levels at weeks 12, 18, and 22. These rats also had significantly decreased antibody titer to tetanus toxin at weeks 8, 12, 18, and 22. Leukocyte and macrophage migration was also significantly inhibited at weeks 8, 12, 18, and 22. The magnitude of the differences between the 10 ppm rats and the controls increased at each later time point. These rats also had a significantly increased albumin to globulin ratio at week 22. Rats consuming diets containing 20 ppm showed all of the same changes as the rats at 10 ppm but to a greater degree. In addition, at weeks 2, 18, and 22, these rats showed a significantly increased albumin to globulin ratio, and at 22 weeks, these rats showed a significant decrease in relative spleen weight. No effect on the relative thymus weight was observed at any dose at any of the times tested.

Data from Banerjee and Hussain (1986) were considered for benchmark modeling analysis. However, only the information regarding serum levels of IgM and IgG, which are presented in a table, could have been subjected to benchmark modeling. Data regarding serum antibody titer to tetanus toxoid as well as leucocyte and macrophage migration inhibition were presented in figures from which only approximate values could be determined. Still, Banerjee and Hussain (1986) indicated in the figures the dose levels at which the responses were significantly different from controls. Therefore, since the lowest dose of 0.45 mg/kg/day (5 ppm in the food) was the NOAEL for serum IgG and IgM levels, antibody titer, and leucocyte and macrophage migration inhibition, the NOAEL/LOAEL approach is preferred for MRL derivation since it includes the three data sets. The study LOAEL was 0.9 mg/kg/day (10 ppm in the food).

[underlined: Dose and end point used for MRL derivation]: 0.45 mg/kg/day; depressed immune response.

[ X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Yes, 0.45 mg/kg/day was calculated by multiplying the dietary level of 5 ppm (5 mg endosulfan/kg diet) by the food factor for male Wistar rats in a subchronic study of 0.09 kg diet/kg body weight/day (EPA 1988).

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: With the exception of a study by Hoechst (1988c), which reported that doses up to 4.5 mg/kg/day given to Wistar rats 2 days before and 10 days after infection with Trichinella spiralis larvae resulted in no effect on the number of worms found in the body at sacrifice, no effect on the thymus or spleen weights, and no effect on the percent lymphocytes or white blood cell count, the study by Banerjee and Hussain (1986) is the only one that has examined immunocompetence in response to an infective agent, and would be helpful to try to replicate it. Vos et al. (1982) reported that serum levels of IgM and IgG were not significantly altered in male Wistar rats dosed with 5 mg/kg/day endosulfan for 3 weeks, but resistance to infection was not tested.

[underlined: Agency Contact (Chemical Manager)]: Jessilynn Taylor

## Endosulfan Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Endosulfan
CAS Numbers: | 115-29-7
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 73
Species: | Rat

[underlined: Minimal Risk Level]: ATSDR adopts the intermediate-duration oral MRL of 0.005 mg/kg/day for the chronic oral MRL, as explained below.

[underlined: Reference]: Banerjee BD, Hussain QZ. 1986. Effect of sub-chronic endosulfan exposure on humoral and cell-mediated immune responses in albino rats. Arch Toxicol 59:279–284 3827596 .

Chronic-duration dietary studies have been conducted in rats, mice, and dogs. Studies in Wistar rats were conducted by FMC (1959b) and Hoechst (1989a), the former used 25 rats per sex per group and the latter 70 rats per sex per group. The results of Hoechst (1989a) were later published as Hack et al. (1995) with emphasis on the neoplastic effects of endosulfan. A 2-year study in NMRI mice was conducted by Hoechst (1988b) and the results were later published as Hack et al. (1995), also with emphasis on the neoplastic effects of endosulfan. A 2-year study in beagle dogs was conducted by FMC (1967) and a 1-year study was conducted by Hoechst (1989c); the former used four dogs per sex per group and the latter used six dogs per sex per group. NCI (1978) conducted long-term studies in Osborne-Mendel rats and B6C3F1 mice. These studies conducted gross and microscopic examination of organs and tissues in addition to hematology and clinical chemistry tests. All of these studies used comparable doses of technical endosulfan (up to approximately 5 mg/kg/day) except for the NCI (1978) study that used doses considerably higher in rats (up to 48 and 22 mg/kg/day, in males and females, respectively). The lowest LOAELs in rats were identified in the Hoechst (1989a) study. The most salient findings in that study included reductions in weight gain and increased incidences of marked progressive glomerulonephrosis in male and female rats from the highest-dose groups. These data are presented in Tables A-1 through A-4. The incidence of aneurysms in the kidneys of male rats was also increased, but there was no dose-response relationship (10/70, 6/70, 17/70, 10/70, and 19/70 in the control and respective increasing dose groups).

Table A-1 Incidence of Marked Progressive Glomerulonephrosis in Male Rats Exposed to Endosulfan for 2 Years

Dose (mg/kg/day) | Total number of rats | Number of rats with lesions
0 | 70 | 20
0.1 | 70 | 18
0.3 | 70 | 22
0.6 | 70 | 24
2.9 | 70 | 30^a^

a p=0.055

Source: Hoechst 1989a

Table A-2 Incidence of Marked Progressive Glomerulonephrosis in Female Rats Exposed to Endosulfan for 2 Years

Dose (mg/kg/day) | Total number of rats | Number of rats with lesions
0 | 70 | 1
0.1 | 70 | 6
0.4 | 70 | 6
0.7 | 70 | 5
3.8 | 70 | 8^a^

a p=0.017

Source: Hoechst 1989a

Table A-3 Data for the Change in Body Weight Gain in Male Rats Exposed to Endosulfan for 2 Years

Dose (mg/kg/day) | Number of animals tested | Weight gain (g) | Standard deviation
0 | 70 | 580 | 124
0.1 | 70 | 570 | 125
0.3 | 70 | 531 | 131
0.6 | 70 | 525 | 115
2.9 | 70 | 479^a^ | 94

a p<0.01

Source: Hoechst 1989a

Table A-4 Data for the Change in Body Weight Gain in Female Rats Exposed to Endosulfan for 2 Years

Dose (mg/kg/day) | Number of animals tested | Weight gain (g) | Standard deviation
0 | 70 | 398 | 105
0.1 | 70 | 350 | 107
0.4 | 70 | 414 | 85
0.7 | 70 | 363 | 92
3.8 | 70 | 328^a^ | 100

a p<0.05

Source: Hoechst 1989a

In mice, the highest dose tested in the Hoechst (1988b) study, 2.9 mg/kg/day, caused a significant reduction in survival rate in females (28 versus 45% in controls). No other significant treatment-related effects were reported in chronic-duration studies in mice. No significant adverse effects were reported in the 2-year study in beagle dogs that received doses of endosulfan of up to 1 mg/kg/day via the diet (FMC 1967). In the 1-year study, the dogs were fed a diet containing 0, 3, 10, or 30 ppm endosulfan (0, 0.2, 0.7, 2 mg/kg/day for males and 0, 0.2, 0.6, 1.8 mg/kg/day for females) (Hoechst 1989c). Dogs fed a diet with ≥45 ppm endosulfan were sacrificed earlier due to severe neurological effects. In the 30 ppm group, three males and two females experienced violent contractions of the abdominal muscles and upper abdomen and convulsive movements of the chap muscles 2.5–6 hours after feeding. Dogs fed the ≤30 ppm diets did not show significant treatment-related alterations in organs and tissues or in hematology values. Among clinical chemistry parameters, dogs in the ≥10 ppm diet groups showed a significant increase in mean serum alkaline phosphatase activity relative to controls (up to approximately 2-fold) beginning at 1.5 months. In the absence of significant changes in other serum enzymes and lack of treatment-related histological alterations in the liver, the investigators did not consider the changes in alkaline phosphatase activity toxicologically significant.

Of the studies mentioned above, the 2-year study in rats conducted by Hoechst (1989a) is the most appropriate for MRL derivation based on the number of animals used per group (n=70), duration of exposure that covered the entire lifespan of the animals, and identification of valid end points, such as kidney lesions and body weight changes, for which dose-response relationships could be constructed. Data sets for marked progressive glomerulonephrosis and body weight changes in male and female rats reported in the Hoechst (1989a) study were analyzed using the BMD approach for MRL derivation. Models in the EPA BMDS (version 2.1.1) were fit to the four data sets to determine potential points of departure for the MRL. The data set for changes in weight gain in female rats proved not suitable for benchmark modeling even after dropping the two highest doses (out of five dose levels tested). Using the criteria for model selection mentioned earlier (see acute-duration oral MRL), the Log-logistic model (BMD_10_ 5.84 mg/kg/day; BMDL_10_ 2.31 mg/kg/day) was selected as the best model to fit the incidence of marked progressive glomerulonephrosis in female rats. The Log-logistic model also provided the best fit for incidence of marked progressive glomerulonephrosis in male rats (BMD_10_ 1.17 mg/kg/day; BMDL_10_ 0.56 mg/kg/day). The Exponential (Model 2) provided the best fit for the decrease in body weight gain in male rats (BMD_10_ 4.60 mg/kg/day; BMDL_10_ 3.41 mg/kg/day). The results of the modeling are shown in Tables A-5, A-6, and A-7.

Table A-5 Model Predictions for Increased Incidence of Marked Progressive Glomerulonephrosis in Female Rats Exposed to Endosulfan for 2 Years

Model | DF | X^2^ | X^2^ Goodness of fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg-day) | BMDL_10_ (mg/kg-day)
Model | DF | X^2^ | X^2^ Goodness of fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg-day) | BMDL_10_ (mg/kg-day)
Logistic | 3 | 3.87 | 0.28 | −0.09 | NA | −1.61 | 187.00 | 5.39 | 3.01
LogLogistic ^c^ ^,^ ^d^ | 3 | 3.85 | 0.28 | −0.17 | NA | −1.55 | 186.84 | 5.84 | 2.31
LogProbit^c^ | NA | NA | NA | NA | NA | NA | NA | NA | NA
Multistage (1-4 degree)^e^ | 3 | 3.85 | 0.28 | −0.16 | NA | −1.56 | 186.86 | 5.79 | 2.41
Probit | 3 | 3.87 | 0.28 | −0.10 | NA | −1.60 | 186.98 | 5.47 | 2.94

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Slope restricted to ≥1.

d Selected model. All models, except for the LogProbit (computation failed) were fit to the data. Gamma and Weibull models were included but are not shown in the table because they defaulted to the Multistage 1 degree model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (LogLogistic Model).

e Betas restricted to >0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; NA = not applicable (BMDL computation failed or the BMD was higher than the highest dose tested)

Table A-6 Model Predictions for Increased Incidence of Marked Progressive Glomerulonephrosis in Male Rats Exposed to Endosulfan for 2 Years

Model | D; F | X^2^ | X^2^ Goodness of fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg-day) | BMDL_10_ (mg/kg-day)
Model | D; F | X^2^ | X^2^ Goodness of fit p-value^a^ | Dose below BMD | Dose above BMD | Over all large st | AIC | BMD_10_ (mg/kg-day) | BMDL_10_ (mg/kg-day)
Logistic | 3 | 0.72 | 0.87 | 0.50 | −0.10 | −0.63 | 441.06 | 1.47 | 0.90
LogLogistic ^c^ ^,^ ^d^ | 3 | 0.57 | 0.90 | 0.40 | −0.13 | −0.58 | 440.91 | 1.17 | 0.56
LogProbit^c^ | 3 | 1.22 | 0.75 | 0.73 | −0.06 | −0.74 | 441.55 | 1.93 | 1.21
Multistage (1-4 degree)^e^ | 3 | 0.63 | 0.89 | 0.44 | −0.12 | −0.60 | 440.96 | 1.28 | 0.68
Probit | 3 | 0.71 | 0.87 | 0.50 | −0.10 | −0.63 | 441.05 | 1.45 | 0.88

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Slope restricted to ≥1.

d Selected model. All models were fit to the data. Gamma and Weibull models were included but are not shown in the table because they defaulted to the Multistage 1 degree model. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold), so the model with the lowest BMDL was selected (LogLogistic model).

e Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; NA = not applicable (BMDL computation failed or the BMD was higher than the highest dose tested)

Table A-7 Model Predictions for Decreased Body Weight Gain in Male Rats Exposed to Endosulfan for 2 Years

Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Mean p-value^b^ | Scaled residuals^c^ | | | AIC | BMD_1SD_ (mg/kg-day) | BMDL_1SD_ (mg/kg-day)
Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Mean p-value^b^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg-day) | BMDL_1SD_ (mg/kg-day)
Constant variance
Linear^d^ | <0.0001 | 0.06 | 0.09 | 0.37 | NA | −1.43 | 3701.35 | 3.99 | 3.00
Non-constant variance
Exponential (model 2) ^e^ ^,^ ^f^ | <0.0001 | 0.43 | 0.29 | 0.30 | NA | −1.33 | 3694.57 | 4.60 | 3.41
Exponential (model 4)^e^ | <0.0001 | 0.43 | 0.89 | NA | NA | NA | 3693.08 | NA | NA
Exponential (model 5)^e^ | <0.0001 | 0.43 | 0.89 | NA | NA | NA | 3693.08 | NA | NA
Hill^e^ | NA | NA | NA | NA | NA | NA | NA | NA | NA
Linear^d^ | <0.0001 | 0.43 | 0.26 | 0.27 | NA | 1.36 | 3694.84 | 4.44 | 3.39
Polynomial (2-degree)^d^ | <0.0001 | 0.43 | 0.26 | 0.27 | NA | 1.36 | 3694.84 | 4.44 | 3.39
Polynomial (3-degree)^d^ | <0.0001 | 0.43 | 0.26 | 0.27 | NA | 1.36 | 3694.84 | 4.44 | 3.37
Polynomial (4-degree)^d^ | <0.0001 | 0.43 | 0.26 | 0.27 | NA | 1.36 | 3694.84 | 4.44 | 3.30
Power^e^ | <0.0001 | 0.43 | 0.26 | 0.27 | NA | 1.36 | 3694.84 | 4.44 | 3.39

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.10 fail to meet conventional good ness-of-fit criteria.

c Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

d Coefficients restricted to be negative.

e Power restricted to ≥1

f Selected model. Constant variance model did not fit variance data, but non-constant variance model did. With non-constant variance model applied, all models except for the Hill (computation failed) provided adequate fit to means. Although the Exponential 4 and 5 models provided adequate fit to the means, the BMD and BMDL computations failed. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 2 model; the Exponential 3 converged onto the Exponential 2).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; NA = not applicable (BMDL computation failed or the BMD was higher than the highest dose tested); SD = standard deviation

The lower BMDL_10_ of 0.56 mg/kg/day is more health protective and is selected as the point of departure for MRL derivation. Applying an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) to the BMDL_10_ of 0.56 mg/kg/day results in a chronic-duration oral MRL of 0.006 mg/kg/day for endosulfan. Since this MRL is slightly higher than the intermediate-duration oral MRL of 0.005 mg/kg/day derived for endosulfan, the intermediate-duration oral MRL, which is protective of potential effects due to chronic exposure to endosulfan, is adopted also for the chronic-duration oral MRL for endosulfan.