# CHAPTER 8 REFERENCES

ACGIH. 2002. Disulfoton. Documentation of the threshold limit values and biological indices. Cincinnati, OH American Conference of Governmental Industrial Hygienists.
Ames RG, Brown SK, Mengle DC, . 1989. Cholinesterase activity depression among California agricultural pesticide applicators. Am J Ind Med 15(2):143–150. 10.1002/ajim.4700150203.2729280
Anderson BJ, Lerman J, Cote CJ. 2019. Pharmacokinetics and pharmacology of drugs used in children. In: A practice of anesthesia for infants and children. 6th ed. Elsevier, 100–176. 10.1016/B978-0-323-42974-0.00007-0.
Aoki Y, Takeda M, Uchiyama M. 1975. Comparative study of methods for the extraction of eleven organophosphorus pesticide residues in rice. J Assoc Off Anal Chem 58(6):1286–1293.1194189
Asman WA, Jorgensen A, Bossi R, . 2005. Wet deposition of pesticides and nitrophenols at two sites in Denmark: measurements and contributions from regional sources. Chemosphere 59(7):1023–1031. 10.1016/j.chemosphere.2004.11.048.
Atkinson R. 1988. Estimation of gas-phase hydroxyl radical rate constants for organic chemicals. Environ Toxicol Chem 7(6):435–442. 10.1002/etc.5620070604.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2019. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/SPL/resources/. November 6, 2019.
Aygun D, Doganay Z, Altintop L, . 2002. Serum acetylcholinesterase and prognosis of acute organophosphate poisoning. J Toxicol Clin Toxicol 40(7):903–910. 10.1081/clt-120016962.12507060
Baldim IM, Souza MC, Souza JC, . 2012. Application of the molecularly imprinted solid-phase extraction to the organophosphate residues determination in strawberries. Anal Bioanal Chem 404(6–7):1959–1966. 10.1007/s00216-012-6327-6.22968680
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.
Basheer C, Alnedhary AA, Rao BS, . 2007. Determination of organophosphorous pesticides in wastewater samples using binary-solvent liquid-phase microextraction and solid-phase microextraction: a comparative study. Anal Chim Acta 605(2):147–152. 10.1016/j.aca.2007.10.006.
Belanger A, Hamilton HA. 1979. Determination of disulfoton and permethrin residues in an organic soil and their translocation into lettuce, onion and carrot. J Environ Sci Health B 14(2):213–226. 10.1080/03601237909372123.438462
Belisle AA, Swineford DM. 1988. Simple, specific analysis of organophosphorus and carbamate pesticides in sediments using column extraction and gas chromatography. Environ Toxicol Chem 7(9):749–752. 10.1002/etc.5620070908.
Bhaskahan R, Kandasawy D, Oblisami G, . 1973. Utilization of disulfoton as carbon and phosphorus sources by soil microflora. Curr Sci 42:835–836.
Bombinski TJ, Dubois KP. 1958. Toxicity and mechanism of action of Di-syston. AMA Arch Ind Health 17(3):192–199.13507723
Bowman MC, Beroza M. 1969. Rapid GLC method for determining residues for fenthion, disulfoton and phorate in corn, milk, grass and feces. J Assoc Off Anal Chem 52:1231–1239.
Bowman BT, Sans WW. 1983. Determination of octanol-water partitioning coefficients (Kow) of 61 organophosphorus and carbamate insecticides and their relationship to respective water solubility (S) values. J Environ Sci Health B 18(6):667–683. 10.1080/03601238309372398.
Brodeur J, Dubois D. 1963. Comparison of acute toxicity of anticholinesterase insecticides to weanling and adult male rats. In: Proceedings of the Society for Experimental Biology and Medicine. Vol. 114. New York, NY: Academic Press, 509–511.
Brokopp CD, Wyatt JL, Gabica J. 1981. Dialkyl phosphates in urine samples from pesticide formulators exposed to disulfoton and phorate. Bull Environ Contam Toxicol 26(4):524–529. 10.1007/BF01622131.7236911
Brusick DJ. 1981. Mutagenicity evaluation of S76 in the mitotic non-disjunction in Saccharomyces cerevisiae strain D6. Study No. T3003064. Kensington, MD: Litton Bionetics Inc.
Brzezinski J. 1969. Catecholamines in urine of rats intoxicated with phosphororganic insecticides. Dissert Pharm Parmacol 21:381–385.
Brzezinski J. 1973. The effect of atropine on the levels of adrenaline and noradrenaline changed by acute poisoning with Disyston in rats. Pol J Pharmacol Pharm 25:611–615.4792483
Bull DL. 1965. Metabolism of di-syston by insects, isolated cotton leaves, and rats. J Econ Entomol 58:249–254. 10.1093/jee/58.2.249.14317629
Capel PD, Giger W, Reichert P, . 1988. Accidental input of pesticides into the Rhine River. Environ Sci Technol 22(9):992–997. 10.1021/es00174a001.22148648
Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the United States. Environ Monit Assess 5(2):155–163. 10.1007/BF00395844.24257992
Carpy S, Klotzsche C, Cerioli A. 1975. Disulfoton: 2-year feeding study in rats. Study no. 47069. Switzerland: Sandoz Inc.
CDC. 2019. National Health and Nutrition Examination Survey: 2011-2012 data documentation, codebook, and frequencies: Organophosphate insecticides - dialkyl phosphate metabolites - urine (OPD_G). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/nchs/nhanes/ContinuousNhanes/Overview.aspx?BeginYear=2011. December 11, 2020.
CDR. 2016. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/2016-chemical-data-reporting-results. December 11, 2020.
Chapman RA, Tolman JH, Cole C. 1994a. The effect of multiple soil applications of disulfoton on enhanced microbial degradation in soil and subsequent uptake of insecticidal chemicals by potato plants. J Environ Sci Health B 29(3):485–506. 10.1080/03601239409372892.8201175
Chapman RA, Harris CR, Tolman JH, . 1993. Further comparison of the persistence in clay loam of single and repeated annual applications of some granular insecticides. J Environ Sci Health B 28(2):151–170. 10.1080/03601239309372820.
Chapman RA, Harris CR, Tolman JH, . 1994b. The persistence of insecticidal chemicals in soils treated with granular formulations of disulfoton and their uptake by potato plants. J Environ Sci Health B 29(2):233–245. 10.1080/03601239409372877.8169317
Chen HH, Sirianni SR, Huang CC. 1982. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4(5):621–624. 10.1002/em.2860040513.7140680
Chen HH, Hsueh JL, Sirianni SR, . 1981. Induction of sister-chromatid exchanges and cell cycle delay in cultured mammalian cells treated with eight organophosphorus pesticides. Mutat Res 88(3):307–316. 10.1016/0165-1218(81)90042-2.7254224
Christenson WR, Wahle BS. 1993. Technical grade disulfoton (DI-SYSTON): a special 6-month feeding study to determine a cholinesterase no-observed-effect level in the rat. Study No. 91-972-IR, Report No. 106336. Stilwell, KS: Miles Inc. Agriculture Division, Toxicology.
Clapp DW, Naylor DV, Lewis GC. 1976. The fate of disulfoton in Portneuf silt loam soil. J Environ Qual 5:207–210.
Clark G, Stavinoha WB. 1971. A permeability change in CNS tissue in chronic poisoning with disulfoton. Life Sci I 10(8):421–423. 10.1016/0024-3205(71)90106-8.4102560
Clark G, Pearson DW. 1973. Learning in chronic disulfoton poisoning. J Gen Psychol 89:305–311. 10.1080/00221309.1973.9710833.4795234
Clark G, Koester AG, Pearson DW. 1971. Exploratory behavior in chronic disulfoton poisoning in mice. Psychopharmacologia 20(2):169–171. 10.1007/BF00404370.5090536
Clewell HJ, Andersen M. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cohen DB. 1986. Groundwater contamination by toxic substances: A California assessment. ACS Symp Ser 315:499–529.
Costa LG, Murphy SD. 1983a. [3H]Nicotine binding in rat brain: alteration after chronic acetylcholinesterase inhibition. J Pharmacol Exp Ther 226(2):392–397.6875853
Costa LG, Murphy SD. 1983b. Unidirectional cross-tolerance between the carbamate insecticide propoxur and the organophosphate disulfoton in mice. Fundam Appl Toxicol 3(5):483–488. 10.1016/s0272-0590(83)80024-4.6642106
Costa LG, Schwab BW, Murphy SD. 1982. Tolerance to anticholinesterase compounds in mammals. Toxicology 25(2–3):79–97. 10.1016/0300-483x(82)90021-x.6760465
Costa LG, Kaylor G, Murphy SD. 1986. Carbachol- and norepinephrine-stimulated phosphoinositide metabolism in rat brain: Effect of chronic cholinesterase inhibition. J Pharmacol Exp Ther 239(1):32–37.3020234
Costa LG, Kaylor G, Murphy SD. 1990. In vitro and in vivo modulation of cholinergic muscarinic receptors in rat lymphocytes and brain by cholinergic agents. Int J Immunopharmacol 12(1):67–75. 10.1016/0192-0561(90)90069-y.2303319
Costa LG, Shao M, Basker K, . 1984. Chronic administration of an organophosphorus insecticide to rats alters cholinergic muscarinic receptors in the pancreas. Chem Biol Interact 48(3):261–269. 10.1016/0009-2797(84)90139-x.6609006
Coupe RH, Manning MA, Foreman WT, . 2000. Occurrence of pesticides in rain and air in urban and agricultural areas of Mississippi, April-September 1995. Sci Total Environ 248(2–3):227–240. 10.1016/s0048-9697(99)00545-8.10805242
CPCR. 1992. Di-Syston. In: Crop protection chemicals reference. 8th ed. New York, NY: Chemical and Pharmaceutical Press, 1160–1171.
Crawford CR, Anderson RH. 1973. Acute oral toxicity of Di-Syston technical to guinea pigs. Mobay Chemical Corporation, Environmental Health Research Institute. MRID: 71872. Report No. 39113. CDL:095640-F.
Crawford CR, Anderson RH. 1974. Acute oral toxicity of several Di-Syston metabolites to female and male rats. Report no. 39687. Stilwell, KS: Mobay Chemical Corporation, Environmental Health Research Institute.
Crawford JM, Hoppin JA, Alavanja MC, . 2008. Hearing loss among licensed pesticide applicators in the agricultural health study. J Occup Environ Med 50(7):817–826. 10.1097/JOM.0b013e31816a8caf.18617838
Croutch CR, Sheets LP. 2000. Data evaluation record: Subject: 032501: 1- and 3-day dermal toxicity study in rats 1% granular disulfoton (MRID# 45239602) (non-guideline study). Washington, DC: U.S. Environmental Protection Agency.
de Faria AM, de Noronha LMS, Dardengo RP, . 2016. Mobility and degradation of disulfoton in coffee culture soil. Environ Technol Innov 5:1–9. 10.1016/j.eti.2015.11.002.
Dillon AP. 1981. Disposal of selected pesticides. In: Pesticide disposal and detoxification: process and techniques. Park Ridge, NJ: Noyes Data Corporation, 421–423, 444, 446.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. December 11, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A. Oak Ridge, TN: U.S. Department of Energy. https://edms3.energy.gov/pac/. April 12, 2020.
dos Anjos JP, de Andrade JB. 2014. Determination of nineteen pesticides residues (organophosphates, organochlorine, pyrethroids, carbamate, thiocarbamate and strobilurin) in coconut water by SDME/GC–MS. Microchem J 112:119–126. 10.1016/j.microc.2013.10.001.
dos Anjos JP, de Andrade JB. 2015. Simultaneous determination of pesticide multiresidues in white wine and rosé wine by SDME/GC-MS. Microchem J 120:69–76. 10.1016/j.microc.2015.01.009.
Doull J. 1957. The acute inhalation toxicity of Di-Syston to rats. Report no. 1802. Chicago, IL: University of Chicago, Department of Pharmacology.
Dragan D, Carpov A. 1987. Microencapsulated organophosphorous insecticides. III. Some aspects on the volatilization of malathion and disulfoton from aqueous suspensions of microcapsules. J Microencapsul 4(2):97–105. 10.3109/02652048709021803.3504503
Draper WM, Crosby DG. 1984. Solar photooxidation of pesticides in dilute hydrogen peroxide. J Agric Food Chem 32(2):231–237. 10.1021/jf00122a014.
DuBois KP. 1957. The dermal toxicity of Di-Syston to rats. Report no. 2063. Chicago, IL: University of Chicago, Toxicity Laboratory.
DuBois KP, Kinoshita FK. 1968. Influence of induction of hepatic microsomal enzymes by phenobarbital on toxicity of organic phosphate insecticides. Proc Soc Exp Biol Med 129(3):699–702. 10.3181/00379727-129-33402.5725078
DuBois KP, Kinoshita FK. 1971. Effect of repeated inhalation exposure of female rats to Di-Syston. Report No. 30571. MRID 87935. Chicago, IL: University of Chicago.
Ecobichon DJ. 1990. Toxic effects of pesticides. In: Klaasen CD, Amdur MO, Doull J, eds. Casarett and Doull’s Toxicology. 4th ed. New York, NY: Pergamon Press, 565–622.
Edgell KW, Jenkins EL, Lopez-Avila V, . 1991. Capillary column gas chromatography with nitrogen-phosphorus detection for determination of nitrogen- and phosphorus-containing pesticides in finished drinking waters: collaborative study. J Assoc Off Anal Chem 74(2):295–309.2050612
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
EPA. 1977. The degradation of selected pesticides in soil: A review of published literature. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600977022. PB272353.
EPA. 1978. Chemical methods for chemical detoxification of disulfoton. Identification and description of chemical deactivation/detoxification methods for the safe disposal of selected pesticides. U.S. Environmental Protection Agency, 71–73. EPA-SW165C. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101EM0F.txt.
EPA. 1980. In vitro microbiological mutagenicity and unscheduled DNA synthesis studies of eighteen pesticides. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA6001790441. PB80133226.
EPA. 1981. Mutagenesis screening of pesticides ‘Drosophila’. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600181017. PB81160848.
EPA. 1984a. In vitro and in vivo mutagenicity studies of environmental chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600184003. PB84138973.
EPA. 1984b. Pesticide fact sheet: Disulfoton. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988. Measurement of hydrolysis rate constants for evaluation of hazardous waste land disposal: Volume 3: Data on 70 chemicals. Athens, GA: U.S. Environmental Protection Agency. EPA600388028. PB38234842.
EPA. 1989. Disulfoton. Drinking water health advisory: Pesticides. U.S. Environmental Protection Agency. Chelsea, MI: Lewis Publishers. 345–362.
EPA. 1989. Proposed amendment to final best demonstrated available technology (BDAT) background document for organophosphorus wastes (KO36 nonwastewaters). Volume 14. Washington, DC: U.S. Environmental Protection Agency. PB90166521. EPA530SW90012N.
EPA. 1993. Land disposal restrictions for newly identified and listed hazardous wastes and hazardous soil; proposed rule. U.S. Environmental Protection Agency. Fed Regist 58(176):48092–48204. https://www.govinfo.gov/content/pkg/FR-1993-09-14/pdf/FR-1993-09-14.pdf. May 12, 2022.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 2000. The use of data of cholinesterase inhibition for risk assessments of organophosphorous and carbamate pesticides. Washington, DC: U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/trac/web/pdf/cholin.pdf. May 12, 2022.
EPA. 2004. Integrated Risk Information System (IRIS); announcement of 2004 program; request for information. U.S. Environmental Protection Agency. Fed Regist 69(26):5971–5976.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA740B19037.
EPA. 2006. Reregistration eligibility decision for disulfoton. Washington, DC: U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/reregistration/web/pdf/disulfoton_red.pdf. May 12, 2022.
EPA. 2008. Potential risks of disulfoton use to federally threatened California red-legged frog (Rana aurora draytonii). Washington, DC: U.S. Environmental Protection Agency. https://www3.epa.gov/pesticides/endanger/litstatus/effects/redleg-frog/disulfoton/determination.pdf. May 12, 2022.
EPA. 2009a. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. May 12, 2022.
EPA. 2009b. The national study of chemical residues in lake fish tissue. U.S. Environmental Protection Agency. EPA823R09006.
EPA. 2010. Disulfoton registration review decision January 2010. U.S. Environmental Protection Agency. Case Number 0102. EPA-HQ-OPP-2009-0054-0016. https://www.regulations.gov/document?D=EPA-HQ-OPP-2009-0054-0016. May 12, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100U7U8.txt. May 12, 2022.
EPA. 2018b. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33. https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol28/pdf/CFR-2018-title40-vol28-sec261-33.pdf. May 12, 2022.
EPA. 2018c. Appendix A to Part 355-The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355. https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol30/pdf/CFR-2018-title40-vol30-part355-appA.pdf. May 12, 2022.
EPA. 2018d. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol30/pdf/CFR-2018-title40-vol30-sec302-4.pdf. May 12, 2022.
EPA. 2018e. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2019a. List of lists: Consolidated list of chemicals subject to the Emergency Planning and Community Right-To-Know Act (EPCRA), Comprehensive Environmental Response, Compensation and Liability Act (CERCLA) and Section 112(r) of the Clean Air Act. U.S. Environmental Protection Agency. EPA550B19003.
EPA. 2019b. Table II. EPCRA Section 313 chemical list for reporting year 2018 (including toxic chemical categories). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2019-03/documents/ry_2018_tri_chemical_list.pdf. May 12, 2022.
EPA. 2021. Chemicals evaluated for carcinogenic potential by the Office of Pesticide Programs, October 27, 2021. Washington, DC: U.S. Environmental Protection Agency. http://npic.orst.edu/chemicals_evaluated.pdf. May 13, 2022.
Eto M. 1974. Disulfoton. In: Organophosphorus pesticides: Organic and biological chemistry. Cleveland, OH: CRC Press, 123–321.
FAO/WHO. 1991. Pesticide residues in food-disulfoton. Report of the Joint Meeting of the FAO Panel of Experts on Pesticide Residues in Food and the Environment and a WHO Expert Group on Pesticide Residues. Rome, Italy: Food and Agriculture Organization of the United Nations and the World Health Organization, 151–172.
Fawade MM, Pawar SS. 1978. Alteration in mixed function oxidase system during thiodemeton (o-o diethyl S-2(ethylthio) ethyl phosphorothioate) toxicity. Indian J Exp Biol 16(4):481–484.680855
Fawade MM, Pawar SS. 1980. Effect of phenobarbital pretreatment on mixed function oxidases & lipid peroxidation during thiodemeton toxicity. Indian J Exp Biol 18(6):645–647.7439951
Fawade MM, Pawar SS. 1983. Effect of NiCl2, CoCl2 & cycloheximide on microsomal drug metabolism & ALA-synthetase during thiodemeton toxicity. Indian J Exp Biol 21(6):343–346.6667989
FDA. 2017a. Pesticide residue monitoring program fiscal year 2014 pesticide report. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-2014-report-and-data. May 12, 2022.
FDA. 2017b. Pesticide residue monitoring program fiscal year 2015 pesticide report. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-2015-report-and-data. May 12, 2022.
FDA. 2018. Pesticide residue monitoring program fiscal year 2016 pesticide report. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-program-reports-and-data. May 12, 2022.
FDA. 2019. Pesticide residue monitoring program fiscal year 2017 pesticide report. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-2017-report-and-data. May 12, 2022.
FDA. 2021a. Substances added to food (formerly EAFUS). U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. February 3, 2021.
FDA. 2021b. Pesticide residue monitoring program fiscal year 2019 pesticide report. U.S. Food and Drug Administration. https://www.fda.gov/media/153142/download. December 28, 2021.
Fisher IJ, Phillips PJ, Bayraktar BN, . 2021. Pesticides and their degradates in groundwater reflect past use and current management strategies, Long Island, New York, USA. Sci Total Environ 752:141895. 10.1016/j.scitotenv.2020.141895.32892047
Fitzgerald BB, Costa LG. 1992. Modulation of M1 and M2 muscarinic receptor subtypes following repeated organophosphate exposure in rats. Toxicol Appl Pharmacol 117(1):122–125. 10.1016/0041-008x(92)90226-i.1440606
Fitzgerald BB, Costa LG. 1993. Modulation of muscarinic receptors and acetylcholinesterase activity in lymphocytes and in brain areas following repeated organophosphate exposure in rats. Fundam Appl Toxicol 20(2):210–216. 10.1006/faat.1993.1028.8449393
Flucke W. 1986. S 276 Technical - Study of subacute dermal toxicity to rabbits. Unpublished Report 14747 from Bayer AG, Institute of Toxicology, Wuppertal-Elberfeld, Germany.
Flucke W. 1988. S 276 Technical grade disulfoton: Study of the subacute dermal toxicity to rabbits. Germany: Bayer Corporation, Stilwell, KS. MRID# 45239601.
Foreman WT, Majewski MS, Goolsby DA, . 2000. Pesticides in the atmosphere of the Mississippi River Valley, part II-air. Sci Total Environ 248(2–3):213–226. 10.1016/s0048-9697(99)00544-6.10805241
Frank R, Logan L. 1988. Pesticide and industrial chemical residues at the mouth of the Grand, Saugeen and Thames rivers, Ontario, Canada 1981-85. Arch Environ Contam Toxicol 17(6):741–754. 10.1007/bf01061980.
Futagami K, Otsubo K, Nakao Y, . 1995. Acute organophosphate poisoning after disulfoton ingestion. J Toxicol Clin Toxicol 33(2):151–155. 10.3109/15563659509000465.7897754
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534. 10.1016/0041-008x(69)90013-1.5787520
Garg AK, Sethi GR. 1980. Persistence of insecticide residues in paddy soil. Ind J Plant Protect 8:157–163.
Gawlik BM, Kettrup A, Muntau H. 2000. Estimation of soil adsorption coefficients of organic compounds by HPLC screening using the second generation of the European reference soil set. Chemosphere 41(9):1337–1347. 10.1016/s0045-6535(00)00015-1.11057570
Gelardi RC, Mountford MK. 1993. Infant formulas: evidence of the absence of pesticide residues. Regul Toxicol Pharmacol 17(2 Pt 1):181–192. 10.1006/rtph.1993.1016.8484026
Gigon PL, Gram TE, Gillette JR. 1969. Studies on the rate of reduction of hepatic microsomal cytochrome P-450 by reduced nicotinamide adenine dinucleotide phosphate: effect of drug substrates. Mol Pharmacol 5(2):109–122.4389181
Gillette JR, Davis DC, Sasame HA. 1972. Cytochrome P-450 and its role in drug metabolism. Annu Rev Pharmacol 12:57–84. 10.1146/annurev.pa.12.040172.000421.4114185
Gillezeau C, Alpert N, Joshi P, . 2019. Urinary dialkylphosphate metabolite levels in US adults-National Health and Nutrition Examination Survey 1999-2008. Int J Environ Res Public Health 16(23):4605. 10.3390/ijerph16234605.31757049
Glooschenko WA, Strachan WM, Sampson RC. 1976. Distribution of pesticides and polychlorinated biphenyls in water, sediments, and seston of the upper Great Lakes-1974. Pestic Monit J 10(2):61–67.826875
Gohre K, Miller GC. 1986. Photooxidation of thioether pesticides on soil surfaces. J Agric Food Chem 34(4):709–713. 10.1021/jf00070a030.
Goldfrank LR, Flomenbaum NE, Lewin NA, . 1990. Disulfoton. In: Goldfrank’s Toxicologic Emergencies. 4th ed. Norwalk, CT: Appleton and Lange, 684–692.
Gómez-Arroyo S, Díaz-Sánchez Y, Meneses-Pérez MA, . 2000. Cytogenetic biomonitoring in a Mexican floriculture worker group exposed to pesticides. Mutat Res 466(1):117–124. 10.1016/s1383-5718(99)00231-4.10751733
Gonzalez-Curbelo MA, Socas-Rodriguez B, Herrero M, . 2017. Dissipation kinetics of organophosphorus pesticides in milled toasted maize and wheat flour (gofio) during storage. Food Chem 229:854–859. 10.1016/j.foodchem.2017.02.148.28372254
Gramatica P, Corradi M, Consonni V. 2000. Modelling and prediction of soil sorption coefficients of non-ionic organic pesticides by molecular descriptors. Chemosphere 41(5):763–777. 10.1016/s0045-6535(99)00463-4.10834380
Greenhalgh R. 1978. Terminal residues of organophosphorus pesticides. Pure Appl Chem 50(5):511–518. 10.1351/pac197850050511.
Hajjar NP, Hodgson E. 1980. Flavin adenine dinucleotide-dependent monooxygenase: its role in the sulfoxidation of pesticides in mammals. Science 209(4461):1134–1136. 10.1126/science.7403873.7403873
Hajjar NP, Hodgson E. 1982. Sulfoxidation of thioether-containing pesticides by the flavin-adenine dinucleotide- dependent monooxygenase of pig liver microsomes. Biochem Pharmacol 31(5):745–752. 10.1016/0006-2952(82)90458-0.7082342
Hallberg GR. 1989. Pesticides pollution of groundwater in the humid United States. Agric Ecosyst Environ 26(3–4):299–367. 10.1016/0167-8809(89)90017-0.
Hanna PJ, Dyer KF. 1975. Mutagenicity of organophosphorus compounds in bacteria and Drosophila. Mutat Res 28(3):405–420. 10.1016/0027-5107(75)90235-3.806014
Harris CI. 1969. Movement of pesticides in soil. J Agric Food Chem 17(1):80–82. 10.1021/jf60161a605.
Harris CR, Chapman RA, Tolman JH, . 1988. A comparison of the persistence in a clay loam of single and repeated annual applications of seven granular insecticides used for corn rootworm control. J Environ Sci Health B 23(1):1–32. 10.1080/03601238809372584.3372939
Hattori H, Suzuki O, Yasuoka T, . 1982. Identification and quantitation of disulfoton in urine and blood of a cadaver by gas chromatography/ mass spectrometry. Jpn J Legal Med 36(3):411–413.
Hayes RH. 1983. Oncogenicity study of disulfoton technical on mice. Study no. 80-271-04. Stilwell, KS: Mobay Chemical Corporation, Corporate Toxicology Department.
Hayes RH. 1985. Chronic feeding/oncogenicity study of technical disulfoton (Di-Syston) with rats. Study no. 82-271-01. Stilwell, KS: Mobay Chemical Corporation, Corporate Toxicology Department.
Hayward SJ, Gouin T, Wania F. 2010. Levels and seasonal variability of pesticides in the rural atmosphere of Southern Ontario. J Agric Food Chem 58(2):1077–1084. 10.1021/jf902898f.20039708
Hebert VR, Miller GC. 1990. Depth dependence of direct and indirect photolysis on soil surfaces. J Agric Food Chem 38(3):913–918. 10.1021/jf00093a069.
Helling CS, Dennison DG, Kaufman DD. 1974. Fungicide movement in soils. Phytopathology 64:1091–1100.
Herbold B. 1980. Dominant lethal test on male mouse to evaluate S276 for mutagenic potential. Report No. 9440. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology.
Herbold B. 1981. Micronucleus test on the mouse to evaluate for mutagenic effect. Report no. 10451. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology.
Herbold B. 1983. POL test on E. coli to evaluate for potential DNA damage. Report No. 12139. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology.
Hikita H, Miyata M, Ishikawa S. 1973. [Experimental study of chronic organophosphate (OP) intoxications in the beagle dog. Activities of cholinesterases and residue of OP]. Nippon Ganka Gakkai Zasshi 77(9):1254–1265. (Japanese)4797101
Hildebrandt A, Estabrook RW. 1971. Evidence for the participation of cytochrome b5 in hepatic microsomal mixed-function oxidation reactions. Arch Biochem Biophys 143(1):66–79. 10.1016/0003-9861(71)90186-x.4397839
Hixson EJ, Hathaway TR. 1986. Effect of disulfoton (DI-SYSTON) on reproduction in rats. Study No. 82-67 l-02. Report No. 90965. Stilwell, KS: Mobay Corporation, Corporate Toxicology Department.
Hoffman K, Welscher CH. 1975. S 276 (disulfoton) chronic toxicity study on dogs (two-year feeding experiment). Report nos. 5618 and 45287. West Germany: AG Bayer.
Holden PW. 1986. [Disulfoton]. In: Pesticides and groundwater quality: Issues and problems in four states. Washington, DC: National Academy Press, 20–21, 44–45, 67, 69.
Hoppin JA, Umbach DM, Long S, . 2017. Pesticides are associated with allergic and non-allergic wheeze among male farmers. Environ Health Perspect 125(4):535–543. 10.1289/EHP315.27384423
Huang CC. 1973. Effect on growth but not on chromosomes of the mammalian cells after treatment with three organophosphorus insecticides. Proc Soc Exp Biol Med 142(1):36–40. 10.3181/00379727-142-36952.4683261
IARC. 2018. Agents classified by the IARC Monographs, volumes 1-123. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/wp-content/uploads/2018/09/List_of_Classifications.pdf. May 12, 2022.
IARC. 2021. Agents classified by the IARC Monographs, volumes 1-128. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. February 3, 2021.
Inukai H, Iyatomi A. 1976. Disulfoton: mutagenicity test on bacterial systems. Report no. 29. Japan: Nitokuno, Agricultural Chemicals Institute, Laboratory of Toxicology.
IRIS. 2002. Disulfoton. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0154_summary.pdf. January 10, 2022.
IRPTC. 1985. IRPTC data profile on: Disulfoton. Geneva, Switzerland: International Register of Potentially Toxic Chemicals, United Nations Environment Programme.
Ishikawa S, Miyata M. 1980. Development of myopia following chronic organophosphate pesticide intoxication: An epidemiological and experimental study. In: Merigan WH, Weiss B, eds. Neurotoxicity of the visual system. New York, NY: Raven Press, 233–254.
Jagannath DR. 1981. Mutagenic evaluation of S276 in the Saccharomyces cerevisiae reverse mutation induction assay. Study No. T4003065. Kensington, MD: Litton Bionetics Inc.
Jones RD, Hastings TF, Landes AM. 1999. Absence of neurovisual effects due to tissue and blood cholinesterase depression in a chronic disulfoton feeding study in dogs. Toxicol Lett 106(2–3):181–190. 10.1016/s0378-4274(99)00064-8.10403662
Jury WA, Focht DD, Farmer WJ. 1987a. Evaluation of pesticide groundwater pollution potential from standard indices of soil-chemical adsorption and biodegradation. J Environ Qual 16(4):422–428. 10.2134/jeq1987.00472425001600040022x.
Jury WA, Winer AM, Spencer WF, . 1987b. Transport and transformation of organic chemicals in the soil-air-water. Ecosystem 99:119–164.
Kadoum AM, Mock DE. 1978. Herbicide and insecticide residues in tailwater pits: water and pit bottom soil from irrigated corn and sorghum fields. J Agric Food Chem 26(1):45–50. 10.1021/jf60215a038.621340
Katz KD, Brooks DE. 2020. Organophosphate toxicity workup. Medscape. https://emedicine.medscape.com/article/167726-workup. June 16, 2022.
Kearney PC, Woolson EA, Plimmer JR, . 1969. Decontamination of pesticides in soils. Residue Rev 29:137–149. 10.1007/978-1-4615-8455-1_10.4900801
Khan H, Marya, Amin S, . 2018. Flavonoids as acetylcholinesterase inhibitors: Current therapeutic standing and future prospects. Biomed Pharmacother 101:860–870. 10.1016/j.biopha.2018.03.007.29635895
Kikuchi H, Suzuki Y, Hashimoto Y. 1981. Increase of beta-glucuronidase activity in the serum of rats administered organophosphate and carbamate insecticides. J Toxicol Sci 6(1):27–35. 10.2131/jts.6.27.7265327
King PH, McCarty PL. 1968. A chromatographic model for predicting pesticide migration in soils. Soil Sci 106:248–261.
King AM, Aaron CK. 2015. Organophosphate and carbamate poisoning. Emerg Med Clin North Am 33(1):133–151. 10.1016/j.emc.2014.09.010.25455666
Klaus AM. 2006a. Data evaluation record: Study type: Non-guideline: Cholinesterase inhibition in rats. MRID 46637101. Scientific data reviews: EPA series 361: Subject: 032501: 6(a)(2) data on disulfoton cholinesterase activity after acute dosing in young adults and 11-day old pups at peak time [MRID# 46589701-46589704], in maternal and fetal rats [MRID# 46635901], and in young adults dose 11 days [MRID# 46637101] and 11-day old pups dosed for 11 days [MRID# 46637101]. Washington, DC: U.S. Environmental Protection Agency.
Klaus AM. 2006b. Data evaluation record: Study type: Non-guideline: Cholinesterase inhibition in rat pups. MRID 46637102. Scientific data reviews: EPA series 361: Subject: 032501: 6(a)(2) data on disulfoton cholinesterase activity after acute dosing in young adults and 11-day old pups at peak time [MRID# 46589701-46589704], in maternal and fetal rats [MRID# 46635901], and in young adults dose 11 days [MRID# 46637101] and 11-day old pups dosed for 11 days [MRID# 46637101]. Washington, DC: U.S. Environmental Protection Agency.
Klaus AM. 2006c. Data evaluation record: Study type: Non-guideline: Cholinesterase inhibition in maternal and fetal rats. MRID 46635901. Scientific data reviews: EPA series 361: Subject: 032501: 6(a)(2) data on disulfoton cholinesterase activity after acute dosing in young adults and 11-day old pups at peak time [MRID# 46589701-46589704], in maternal and fetal rats [MRID# 46635901], and in young adults dose 11 days [MRID# 46637101] and 11-day old pups dosed for 11 days [MRID# 46637101]. Washington, DC: U.S. Environmental Protection Agency.
Klotzsche C. 1972. Disulfoton, 90 day feeding study in rats. Switzerland: Sandoz Agroforschung. Report No. 88585.
Knight R, Khondoker M, Magill N, . 2018. A systematic review and meta-analysis of the effectiveness of acetylcholinesterase inhibitors and memantine in treating the cognitive symptoms of dementia. Dement Geriatr Cogn Disord 45(3–4):131–151. 10.1159/000486546.29734182
Krishnan K, Andersen ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kurt-Karakus PB, Teixeira C, Small J, . 2011. Current-use pesticides in inland lake waters, precipitation, and air from Ontario, Canada. Environ Toxicol Chem 30(7):1539–1548. 10.1002/etc.545.21472774
Kutz FW. 1983. Chemical exposure monitoring. Residue Rev 85:277–292. 10.1007/978-1-4612-5462-1_20.6828798
Kutz FW, Carey AE. 1986. Pesticides and toxic substances in the environment. J Arboric 12:92–95.
Lamb DW, Hixson EJ. 1983. Embryotoxic and teratogenic effects of disulfoton. Study no. 81-611-02. Kansas City, MO: Mobay Chemical Corporation.
Lee SGK, Hanna LA, Johnston K, . 1985. Excretion and metabolism of Di-Syston in rats. Unpublished Report MR90946 from Mobay Corporation, USA.
Lide DR. 2005. Disulfoton. In: CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, 3–244, 243–245, 216–236.
Light DR, Waxman DJ, Walsh C. 1982. Studies on the chirality of sulfoxidation catalyzed by bacterial flavoenzyme cyclohexanone monooxygenase and hog liver flavin adenine dinucleotide containing monooxygenase. Biochemistry 21(10):2490–2498. 10.1021/bi00539a031.7093199
Litterst CL, Lichtenstein EP, Kajiwara K. 1969. Effects of insecticides on growth of HeLa cells. J Agric Food Chem 17(6):1199–1203. 10.1021/jf60166a047.
Lockridge O, Norgren RB, Johnson RC, . 2016. Naturally occurring genetic variants of human acetylcholinesterase and butyrylcholinesterase and their potential Impact on the risk of toxicity from cholinesterase inhibitors. Chem Res Toxicol 29:1381–1392.27551784
Luke MA, Masumoto HT, Cairns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke Multiresidue Methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71(2):415–433.3384794
Lynch AM, Robinson SA, Wilcox P, . 2008. Cycloheximide and disulfoton are positive in the photoclastogencity assay but do not absorb UV irradiation: another example of pseudophotoclastogenicity? Mutagenesis 23(2):111–118. 10.1093/mutage/gem053.18227081
March RB, Fukuto TR, Metcalf RL. 1957. Metabolism of p32-dithio-systox in the white mouse and American cockroach. Riverside, California: University of California, Citrus Experiment Station. MRID 83215.
Matsuda H, Seo Y, Kakizaki E, . 2000. Changes in mRNA expression levels of synaptic- and target tissue-specific proteins after organophosphate exposure. Leg Med (Tokyo) 2(2):55–63. 10.1016/s1344-6223(00)80024-3.12935443
McCarty PL, King PH. 1966. The movement of pesticides in soils. Engin Bull Purdue Univ 50(2):156–171.
McCarty RT, Haufler M, Osborn MG, . 1969. Oral toxicity of four organophosphate insecticides to farm livestock. Am J Vet Res 30(7):1149–1153.5815922
McPhillips JJ. 1969a. Altered sensitivity to drugs following repeated injections of a cholinesterase inhibitor to rats. Toxicol Appl Pharmacol 14(1):67–73. 10.1016/0041-008x(69)90165-3.4304689
McPhillips JJ. 1969b. Subsensitivity of the rat ileum to cholinergic drugs. J Pharmacol Exp Ther 166(2):249–254.5776982
Menzer RE, Fontanilla EL, Ditman LP. 1970. Degradation of disulfoton and phorate in soil influenced by environmental factors and soil type. Bull Environ Contam Toxicol 5(1):1–5. 10.1007/BF01545114.24185714
Menzie CM. 1972. Fate of pesticides in the environment. Annu Rev Entomol 17:199–222. 10.1146/annurev.en.17.010172.001215.4550533
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299. 10.1016/0045-6535(93)90355-9.
Mihail F. 1978. S 276 (Disyston active ingredient) acute toxicity studies. Report no. 7602a. West Germany: AG Bayer, Institut fur Toxicologic.
Miller GC, Hebert VR, Miller WW. 1989. Effect of sunlight on organic contaminants at the atmosphere-soil interface. SSSA Spec Publ 22:99–110. 10.2136/sssaspecpub22.c5.
Minyard JP, Roberts WE. 1991. State findings on pesticide residues in food-1988 and 1989. J Assoc Off Anal Chem 74(3):438–452.1874687
Mitchell TH, Ruzicka JH, Thomson J, . 1968. The chromatographic determination of organophosphorus pesticides: Part III. The effect of irradiation on the parent compounds. J Chromatog A 32:17–23. 10.1016/S0021-9673(01)80468-4.
Moon J, Chun B. 2014. Utility of red blood cell acetylcholinesterase measurement in mechanically ventilated subjects after organophosphate poisoning. Respir Care 59(9):1360–1368. 10.4187/respcare.02916.24865421
Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res Genet Toxicol 116(3–4):185–216. 10.1016/0165-1218(83)90059-9.
Moss DE. 2020. Improving anti-neurodegenerative benefits of acetylcholinesterase inhibitors in Alzheimer’s disease: are irreversible inhibitors the future? Int J Mol Sci 21(10) 10.3390/ijms21103438.
Mossman DJ, Schnoor JL, Stumm W. 1988. Predicting the effects of a pesticide release to the Rhine River. J Water Pollut Control Fed 60(10):1806–1812.
Mostaghimi S, McClellan PW, Cooke RA. 1993. Pesticide contamination of groundwater in Virginia: BMP impact assessment. Water Sci Technol 28(3–5):379–387.
Muhlmann K, Schrader G. 1957. [Hydrolysis of phosphoric acid ester insecticides]. Z Naturforschg [B] 12:196–203. (German)
Muir DC, Teixeira C, Wania F. 2004. Empirical and modeling evidence of regional atmospheric transport of current-use pesticides. Environ Toxicol Chem 23(10):2421–2432. 10.1897/03-457.15511103
Murphy SD. 1986. Toxic effects of pesticides. In: Klaasen CD, Amdur MO, Doull J, eds. Casarett and Doull’s Toxicology. 3rd ed. New York, NY: Pergamon Press, 519–581.
Murty KV, Raju DS, Sharma CB. 1983. Cytogenetic hazards from agricultural chemicals: 7. Herbicides, fungicides and insecticides screened for effects on chiasmata in Hordeum vulgare. Biol Zentralbl 102:571–576.
Musshoff F, Junker H, Madea B. 2002. Simple determination of 22 organophosphorous pesticides in human blood using headspace solid-phase microextraction and gas chromatography with mass spectrometric detection. J Chromatogr Sci 40(1):29–34. 10.1093/chromsci/40.1.29.11866384
Mwila K, Burton MH, Van Dyk JS, . 2013. The effect of mixtures of organophosphate and carbamate pesticides on acetylcholinesterase and application of chemometrics to identify pesticides in mixtures. Environ Monit Assess 185(3):2315–2327. 10.1007/s10661-012-2711-0.22684846
Myram C, Forrest JD. 1969. The application of pesticide granules from the air. Chem Ind 52:1851–1852.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences/National Research Council. National Academy Press, 15–35.
Nash RG. 1974. Plant uptake of insecticides, fungicides and fumigants from soils. In: Guenzi WD, Ahlrichs JL, Chesters G, ., eds. Pesticides in soil and water. Madison, WI: Soil Science of America Inc. Publishers, 257–313.
Neupane D, Jors E, Brandt L. 2014. Pesticide use, erythrocyte acetylcholinesterase level and self-reported acute intoxication symptoms among vegetable farmers in Nepal: a cross-sectional study. Environ Health 13:98.25409889
NIOSH. 2017. NIOSH skin notation profile: Disulfoton. Cincinnati, OH: National Institute for Occupational Safety and Health. Publication No. 2017-185. https://www.cdc.gov/niosh/docs/2017-185/2017-185.pdf?id=10.26616/NIOSHPUB2017185. May 12, 2022.
NIOSH. 2018. Disulfoton. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0245.html. May 12, 2022.
NIST. 2018. Disulfoton. National Institute of Standards and Technology, U.S. Department of Commerce. https://webbook.nist.gov/cgi/inchi?ID=C298044&Mask=4#Thermo-Phase. October 8, 2019.
NLM. 2021. PubChem: Disulfoton. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/disulfoton. December 28, 2021.
Norman AW, Henry HL. 2015. Hormones of the adrenal medulla. In: Hormones. 3rd ed. Academic Press, 239–253. 10.1016/B978-0-08-091906-5.00011-2.
NPIRS. 2021. Active ingredient information. National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/chemical.aspx. December 28, 2021.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program. https://ntp.niehs.nih.gov/whatwestudy/assessments/cancer/roc/index.html#toc1. January 10, 2022.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. December 16, 2021.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. December 16, 2021.
OSHA. 2022. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55. May 10, 2022.
Osweiler GD, Carson TL, Buck WB, . 1985. Organophosphorous and carbamate insecticides. In: Clinical and diagnostic veterinary toxicology. 3rd ed. Dubuque, IA: Kendall/Hunt Publishing Co., 298–317.
Panda BB. 1983. Effect of insecticides oxydemeton methyl and thiodemeton on the mitotic and meiotic chromosomes of barley. Environ Exp Bot 23(4):293–296. 10.1016/0098-8472(83)90002-3.
Pardo LA, Beane Freeman LE, Lerro CC, . 2020. Pesticide exposure and risk of aggressive prostate cancer among private pesticide applicators. Environ Health 19(1):30. 10.1186/s12940-020-00583-0.32138787
Pawar SS, Fawade MM. 1978. Alerations in the toxicity of thiodemeton due to the pretreatment of inducers, substrates and inhibitors of mixed function oxidase system. Bull Environ Contam Toxicol 20(1):805–810. 10.1007/bf01683604.749979
Plumb RH. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Groundwater Monit Remediat 11(2):157–164. 10.1111/j.1745-6592.1991.tb00378.x.
Poulsen LL. 1981. Organic sulfur substrates for microsomal flavin-containing monooxygenase. Rev Biochem Toxicol 3:33–49.
Prasad DRMM, Jirli PS, Mahesh M, . 2013. Relevance of plasma cholinesterase to clinical findings in acute organophosphorous poisoning. Asia Pacific J Med Toxicol 2(1):23–27. 10.22038/APJMT.2013.546.
Puhl RJ, Fredrickson DR. 1975. The metabolism and excretion of Di-Syston by rats. Report no. 44261. Kansas, MO: Mobay Chemical Corporation, Chemagro Agricultural Division.
Putnam DL. 1987. Sister chromatid exchange in Chinese hamster ovary (CHO) cells. Study No. T51596.334. Bethesda, MD: Microbiological Associates Inc.
Racke KD. 1992. Degradation of organophosphorus insecticides in environmental matrices. In: Chambers JE, Levi PE, eds. Organophosphates: Chemistry, fate, and effects. San Diego, CA: Academic Press, 47–78.
Rao SL, McKinley WP. 1969. Metabolism of organophosphorus insecticides by liver homogenates from different species. Can J Biochem 47(12):1155–1159. 10.1139/o69-186.4391423
Rao PSC, Homsby AG, Jessup RE. 1985. Indices for ranking the potential for pesticide contamination of groundwater. Proc Soil Crop Sci Soc Fla 44:1–8.
RePORTER. 2021. Disulfoton. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. December 5, 2019.
Rivett KF, Bhatt A, Street AE, . 1972. Thio-dementon oral toxicity to mice: dietary administration for 3 months. Huntington Research Centre. 5505/72/901.
Robert JR, Reigart JR. 2013. Organophosphate insecticides. In: Recognition and management of pesticide poisonings. 6th ed. Washington DC: U.S. Environmental Protection Agency, Office of Pesticide Programs, 43–55.
Robinson CP, Smith PW, Endecott BR. 1978. Depression of cholinesterase activity by ethylestrenol in organophosphorus-poisoned and normal rats. Toxicol Appl Pharmacol 44(1):207–211. 10.1016/0041-008x(78)90299-5.675690
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Ryan LC, Endecott BR, Hanneman GD, . 1970. Effects of an organophosphorus pesticide on reproduction in the rat. Department of Transportation, Federal Aviation Administration, Office of Aviation Medicine. AD 709327.
Sandhu SS, Waters MD, Simmon VF, . 1985. Evaluation of the genotoxic potential of certain pesticides used in Pakistan. Basic Life Sci 34:185–219. 10.1007/978-1-4684-4976-1_14.4062793
Sapozhnikova Y, Bawardi O, Schlenk D. 2004. Pesticides and PCBs in sediments and fish from the Salton Sea, California, USA. Chemosphere 55(6):797–809. 10.1016/j.chemosphere.2003.12.009.15041284
Savage EP, Bagby JR, Mounce L, . 1971. Pesticide poisonings in rural Colorado. Rocky Mt Med J 68(4):29–33.
Schafer EW. 1972. The acute oral toxicity of 369 pesticidal, pharmaceutical and other chemicals to wild birds. Toxicol Appl Pharmacol 21(3):315–330. 10.1016/0041-008x(72)90151-2.5027965
Schafer EW, Bowles WA. 1985. Acute oral toxicity and repellency of 933 chemicals to house and deer mice. Arch Environ Contam Toxicol 14(1):111–129. 10.1007/bf01055769.3977403
Schattenberg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J Assoc Off Anal Chem Int 75(5):925–933.
Schroeder WH, Dobson M, Kane DM, . 1987. Toxic trace elements associated with airborne particulate matter: a review. JAPCA 37(11):1267–1285. 10.1080/08940630.1987.10466321.3327920
Schwab BW, Murphy SD. 1981. Induction of antichloinesterase tolerance in rats with doses of disulfoton that produce no cholinergic signs. J Toxicol Environ Health 8(1–2):199–204. 10.1080/15287398109530063.7328703
Schwab BW, Costa LG, Murphy SD. 1983. Muscarinic receptor alterations as a mechanism of anticholinesterase tolerance. Toxicol Appl Pharmacol 71(1):14–23. 10.1016/0041-008x(83)90041-8.6636179
Schwab BW, Hand H, Costa LG, . 1981. Reduced muscarinic receptor binding in tissues of rats tolerant to the insecticide disulfoton. Neurotoxicology 2(4):635–647.7200580
Shaw II HR. 1975. The metabolism of DI-SYSTON in soil. Research and Development Department, Chemagro Division of Baychem Corporation. Report No. 40234.
Shaydenfish D, Wongtangman K, Eikermann M, . 2020. The effects of acetylcholinesterase inhibitors on morbidity after general anesthesia and surgery. Neuropharmacology 173:108–134. 10.1016/j.neuropharm.2020.108134.
Sheets LP. 1993a. An acute oral neurotoxicity screening study with technical grade disulfoton (DI-SYSTON) in rats. Study No. 92-412-OB, Report No. 103992. Stilwell, KS: Miles Inc. Agriculture Division, Toxicology.
Sheets LP. 1993b. A subchronic dietary neurotoxicity screening study with technical grade disulfoton (DI-SYSTON) in Fischer 344 rats. Study No. 92-472-HS, Report No. 106332. Stilwell, Kansas: Miles Inc. Agriculture Division, Toxicology.
Sheets LP. 2005. Data evaluation record: Disulfoton: Study type: Developmental neurotoxicity study - rat; OPPTS 870.6300: MRID 45827601. Washington, DC: U.S. Environmental Protection Agency.
Shentema MG, Kumie A, Bratveit M, . 2020. Pesticide use and serum acetylcholinesterase levels among flower farm workers in Ethiopia-A cross-sectional study. Int J Environ Res Public Health 17(3):964. 10.3390/ijerph17030964.32033179
Shiotsuka RN. 1988. Pilot assay to assess cholinesterase activity in rats exposed by inhalation to technical grade disulfoton. Study No. 88-941-AG. Report No. 98358. Stilwell, KS: Mobay Corporation, Corporate Toxicology Department.
Shiotsuka RN. 1989. Subchronic inhalation toxicity study of technical grade disulfoton (DI-SYSTON) in rats. Study No. 88-141-UA. Report No. 99648. Stilwell, KS: Mobay Corporation, Corporate Toxicology Department.
Shirasu Y, Moriya M, Tezuka H, . 1982. Mutagenicity screening studies on pesticides. In: Environmental mutagens and carcinogens: Proceedings of the 3rd International Conference on Environmental Mutagens, Tokyo, Mishima, and Kyoto, September 21-27, 1981. New York: A.R. Liss, 331–335.
Shirasu Y, Moriya M, Tezuka H, . 1984. Mutagenicity of pesticides. Environ Sci Res 31:617–624.
Singh BD, Singh Y, Sarma MDRK, . 1977. Cytogenetic aberrations and morphological changes induced by insecticide treatments of barley seed. Indian J Exp Biol 15:688–691.
Sipes IG, Gandolfi AJ. 1986. Biotransformation of toxicants. In: Klaasen CD, Andur MO, Doull J, eds. Casarett and Doull’s toxicology. 3rd ed. New York, NY: Macmillan Publishing Co., 64–98.
Sittig Me. 1980. Disulfoton. In: Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 695–696.
Smith C, Kerr K, Sadripour A. 2008. Pesticide exports from U.S. ports, 2001-2003. Int J Occup Environ Health 14(3):176–186. 10.1179/oeh.2008.14.3.176.18686717
Smulders CJ, Bueters TJ, Vailati S, . 2004. Block of neuronal nicotinic acetylcholine receptors by organophosphate insecticides. Toxicol Sci 82(2):545–554. 10.1093/toxsci/kfh269.15342957
Smyser BP, Sabourin PJ, Hodgson E. 1985. Oxidation of pesticides by purified microsomal FAD-containing monooxygenase from mouse and pig liver. Pestic Biochem Physiol 24(3):368–374. 10.1016/0048-3575(85)90149-x.
Spalding RF, Snow DD. 1989. Stream levels of agrichemicals during a spring discharge event. Chemosphere 19(8–9):1129–1140. 10.1016/0045-6535(89)90061-1.
Stavinoha WB, Ryan LC, Smith PW. 1969. Biochemical effects of an organophosphorus cholinesterase inhibitor on the rat brain. Ann N Y Acad Sci 160(1):378–382. 10.1111/j.1749-6632.1969.tb15859.x.5257404
Stevens JT, Greene FE. 1974. Alteration of hepatic microsomal metabolism of male mice by certain anticholinesterase insecticides. Bull Environ Contam Toxicol 11(6):538–544. 10.1007/BF01685011.4154787
Stevens JT, Stitzel RE, McPhillips JJ. 1972a. Effects of anticholinesterase insecticides on hepatic microsomal metabolism. J Pharmacol Exp Ther 181(3):576–583.4624402
Stevens JT, Stitzel RE, McPhillips JJ. 1972b. The effects of subacute administration of anticholinesterase insecticides on hepatic microsomal metabolism. Life Sci 11(8):423–431. 10.1016/0024-3205(72)90250-0.
Stevens JT, Greene FE, Stitzel RE. 1973. Effects of anticholinesterase insecticides on mouse and rat liver microsomal mixed function oxidase. In: Deichmann WB, ed. Pesticides and the environment: A continuing controversy. New York: Intercontinental Medical Book Corporation, 489–501.
Storm JE, Rozman KK, Doull J. 2000. Occupational exposure limits for 30 organophosphate pesticides based on inhibition of red blood cell acetylcholinesterase. Toxicology 150(1–3):1–29. 10.1016/s0300-483x(00)00219-5.10996660
Strelitz J, Engel LS, Keifer MC. 2014. Blood acetylcholinesterase and butyrylcholinesterase as biomarkers of cholinesterase depression among pesticide handlers. Occup Environ Med 71(12):842–847. 10.1136/oemed-2014-102315.25189163
Su MQ, Kinoshita FK, Frawley JP, . 1971. Comparative inhibition of aliesterases and cholinesterase in rats fed eighteen organophosphorus insecticides. Toxicol Appl Pharmacol 20(2):241–249. 10.1016/0041-008x(71)90050-0.5133254
Suzuki H, Ishikawa S. 1974. Ultrastructure of the ciliary muscle treated by organophosphate pesticide in beagle dogs. Br J Ophthalmol 58(11):931–940. 10.1136/bjo.58.11.931.4457106
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters, octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Syakalima M, Choongo K, Mwenechanya R, . 2006. Pesticide/herbicide pollutants in the Kafue River and a preliminary investigation into their biological effect through catalase levels in fish. Jpn J Vet Res 54(2–3):119–128.17201197
Szeto SY, Brown MJ. 1982. Gas-liquid chromatographic methods for the determination of disulfoton, phorate, oxydemeton-methyl, and their toxic metabolites in asparagus tissue and soil. J Agric Food Chem 30(6):1082–1086. 10.1021/jf00114a019.
Szeto SY, Vernon RS, Brown MJ. 1983a. Degradation of disulfoton in soil and its translocation into asparagus. J Agric Food Chem 31(2):217–220. 10.1021/jf00116a008.6853850
Szeto SY, Mackenzie JR, Vernon RS, . 1983b. The degradation of disulfoton in lettuce after applications for control of the lettuce aphid, Nasonovia ribisnigri (Mosley). Journal of Environmental Science and Health, Part B 18(6):725–734. 10.1080/03601238309372403.
Takase I, Oyama H. 1985. Uptake and bioconcentration of disulfoton and its oxidation compounds in carp, Cyprinus carpio L. J Pesticide Sci 10(1):47–53.
Taylor RE. 1965a. Di-Syston, three generation rat breeding studies. Report No. 17164. Harris Laboratories, Inc.
Tesh JM, Ross FW, Secher RG. 1982. Effects of oral administration upon pregnancy in the rabbit. Report no. R 2351. Essex, England: Life Science Research.
Thetkathuek A, Yenjai P, Jaidee W, . 2017. Pesticide exposure and cholinesterase levels in migrant farm workers in Thailand. J Agromedicine 22(2):118–130. 10.1080/1059924X.2017.1283276.28139185
Thomas RG. 1990. Volatilization from water. In: Lyman WS, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15–16.
Thornton JS, Hurley JB, Obrist JJ. 1976. Soil thin-layer mobility of twenty-four pesticides chemicals. Research and Development Department, Chemagro Agricultural Division, Mobay Chemical Corp. Report No. 51016.
Thyssen JT. 1978. Acute inhalation toxicity. Report No. 7827. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology.
Thyssen JT. 1980. Disulfoton (S 276). The active ingredient of di-syston subacute inhalation study on rats. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology. 83-T-80. Bayer Report No. 9065. Mobay ACD Report No. 69361.
Tomizawa C. 1975. Degradation of organophosphorus pesticides in soils with special reference to unaerobic soil conditions. Environ Qual Saf 4:117–127.1193050
Tomizawa C. 1980. Biological accumulation of pesticides in an ecosystem-evaluation of biodegradability and ecological magnification of rice pesticides by a model ecosystem. Jpn Agric Res Q 14(3):143–149.
Tsuda T, Kojima M, Harada H, . 1997. Relationships of bioconcentration factors of organophosphate pesticides among species of fish. Comp Biochem Physiol C Toxicol Pharmacol 116(3):213–218. 10.1016/s0742-8413(96)00196-x.
Tynes RE, Hodgson E. 1985. Magnitude of involvement of the mammalian flavin-containing monooxygenase in the microsomal oxidation of pesticides. J Agric Food Chem 33(3):471–479. 10.1021/jf00063a036.
Uga S, Ishikawa S, Mukuno K. 1977. Histopathological study of canine optic nerve retina treated by organophosphate pesticide. Invest Ophthalmol Vis Sci 16(9):877–881.893037
USGS. 2002. Pesticides in surface water of the Yakima River Basin, Washington 1999-2000. Their occurrence and an assessment of factors affecting concentrations and loads. Portland, OR: U.S. Geological Survey. https://pubs.usgs.gov/wri/2001/4211/wri01-4211.pdf. December 28, 2021.
USGS. 2021. Estimated annual agricultural pesticide use, pesticide use maps – Disulfoton. U.S. Geological Survey. https://water.usgs.gov/nawqa/pnsp/usage/maps/show_map.php?year=2017&map=DISULFOTON&hilo=L&disp=Disulfoton. December 28, 2021.
Usui K, Hayashizaki Y, Minagawa T, . 2012. Rapid determination of disulfoton and its oxidative metabolites in human whole blood and urine using QuEChERS extraction and liquid chromatography-tandem mass spectrometry. Leg Med (Tokyo) 14(6):309–316. 10.1016/j.legalmed.2012.06.005.22818267
Vaughn G, Deiniger E, Doull J. 1958. Determination of a safe dietary level of Di-Syston for dogs. Department of Pharmacology, University of Chicago. Chicago, IL: Department of Pharmacology, University of Chicago.
VonRumker R, Lawless EW, Meiners AF. 1974. Production, distribution, use and environmental impact potential of selected pesticides. NTIS PB238 795.
Wanner O, Egli T, Fleischmann T, . 1989. Behavior of the insecticides disulfoton and thiometon in the Rhine River: a chemodynamic study. Environ Sci Technol 23(10):1232–1242. 10.1021/es00068a007.
Warnick SL, Eldredge JD. 1972. Human and environmental exposure to pesticides in Utah. Proc Utah Acad Sci Arts Lett 49:1972.
Waters MD, Nesnow S, Simmon VF, . 1981. Pesticides: Mutagenic and carcinogenic potential. ACS Symp Ser 160:89–113.
Waters MD, Sandhu SS, Simmon VF, . 1982. Study of pesticide genotoxicity. Basic Life Sci 21:275–326. 10.1007/978-1-4684-4352-3_23.7150196
Wauchope RD, Buttler TM, Hornsby AG, . 1992. The SCS/ARS/CES pesticide properties database for environmental decision-making. Rev Environ Contam Toxicol 123:1–155.1732992
Wauchope RD, Yeh S, Linders JB, . 2002. Pesticide soil sorption parameters: theory, measurement, uses, limitations and reliability. Pest Manag Sci 58(5):419–445. 10.1002/ps.489.11997969
Waxman DJ, Light DR, Walsh C. 1982. Chiral sulfoxidations catalyzed by rat liver cytochromes P-450. Biochemistry 21(10):2499–2507. 10.1021/bi00539a032.7093200
Weil CS, Condra NI, Carpenter CP. 1971. Correlation of 4-hour vs. 24-hour contact skin penetration toxicity in the rat and rabbit and use of the former for predictions of relative hazard of pesticide formulations. Toxicol Appl Pharmacol 18(3):734–742. 10.1016/s0041-008x(71)80028-5.5569841
WHO. 1976. Disulfoton. 1975 Evaluations of some pesticide residues in food: The monographs. Geneva, Switzerland: World Health Organization. 199–212. WHO Pesticide Residue Series no. 5.
WHO. 2012. WHO guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. May 12, 2022.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. May 12, 2022.
Winter CK. 1992. Dietary pesticide risk assessment. Rev Environ Contam Toxicol 127:23–67. 10.1007/978-1-4613-9751-9_2.1631351
Winterlin W, Seiber JN, Craigmill A, . 1989. Degradation of pesticide waste taken from a highly contaminated soil evaporation pit in California. Arch Environ Contam Toxicol 18(5):734–747. 10.1007/BF01225011.
Wolfe HR, Staiff DC, Armstrong JF, . 1978. Exposure of fertilizer mixing plant workers to disulfoton. Bull Environ Contam Toxicol 20(1):79–86. 10.1007/bf01683489.698422
Worek F, Koller M, Thiermann H, . 2005. Diagnostic aspects of organophosphate poisoning. Toxicology 214(3):182–189. 10.1016/j.tox.2005.06.012.16051411
WQP. 2021. Water quality portal: Disulfoton. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. December 28, 2021.
Wysocka-Paruszewska B. 1970. Urine level of 4-hydroxy-3-methoxymandelic acid in urine of rats poisoned with phosphorus organic insecticides. Diss Pharm Pharmacol 22:485–489.
Wysocka-Paruszewska B. 1971. Changes in the urine level of 4-hydroxy-3-methoxymandelic acid in rats related to the degree of intoxication with Di-Syston. Diss Pharm Pharmacol 23:271–274.
Yagle K, Costa LG. 1996. Effects of organophosphate exposure on muscarinic acetylcholine receptor subtype mRNA levels in the adult rat. Neurotoxicology 17(2):523–530.8856746
Yang LL. 1988. CHO/HGPRT mutation assay. Study No. T5196.332. Bethesda, MD: Microbiological Associates Inc.
Yashiki M, Kojima T, Ohtani M, . 1990. Determination of disulfoton and its metabolites in the body fluids of a Di-Syston intoxication case. Forensic Sci Int 48(2):145–154. 10.1016/0379-0738(90)90107-a.2283138
Yess NJ. 1991. FDA monitoring program. Residues in foods-1990. J Assoc Off Anal Chem 74(5):121A–141A.
Yess NJ, Houston MG, Gunderson EL. 1991. Food and Drug Administration pesticide residue monitoring of foods: 1978-1982. J Assoc Off Anal Chem 74(2):265–272.2050608
Zendzian RP. 2000. Dermal absorption of pesticides in the rat. AIHAJ 61(4):473–483. 10.1080/15298660008984558.10976676
Zepp RG, Baughman GL. 1978. Prediction of photochemical transformation of pollutants in the aquatic environment. In: Hutzinger U, Van Lilyveld IH, Zoeteman BCJ, eds. Aquatic pollutants. Oxford: Pergamon Press, 237–263.
Zepp RG, Baughman GL, Schlotzhauer PF. 1981. Comparison of photochemical behavior of various humic substances in water. I. Sunlight induced reactions of aquatic pollutants photosensitized by human substances. Chemosphere 10:109–117.
Zivkovic AR, Schmidt K, Brenner T, . 2014. Plasma cholinesterase activity as diagnostic marker for systemic inflammation [abstract P219]. Critical Care 18(Suppl 1):S78. 10.1186/cc13409.