# VERSION HISTORY

Date | Description
August 2022 | Final toxicological profile released
July 2021 | Draft for public comment toxicological profile released
September 2011 | Addendum to the toxicological profile released
August 1995 | Final toxicological profile released