# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding disulfoton in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for disulfoton.

In 2009, disulfoton was cancelled for use in pesticide products in the United States (EPA 2010). Disulfoton is on the list of chemicals appearing in the Emergency Planning and Community Right-to-Know Act of 1986 (EPCRA); the Comprehensive Environmental Response, Compensation and Liability Act; and Section 112(r) of the Clean Air Act (EPA 2019a). Disulfoton is considered an extremely hazardous substance (EHS) under 40 CFR part 355, and facilities with disulfoton in quantities greater than or equal to 500 pounds must report (EPA 2018c). Disulfoton was not on the EPCRA Section 313 Chemical List for Reporting Year 2018, and was not reported to TRI (EPA 2019b). Under CERCLA, disulfoton is subject to reporting to the National Response Center in quantities greater than or equal to one pound (EPA 2018d).

Under the Resource Conservation and Recovery Act (RCRA), disulfoton is listed as a hazardous waste when it is a discarded commercial chemical product, off-specification species (e.g., a product that does not meet purity or property specifications), container residue, and spill residue (EPA 2018b).

Table 7-1 Regulations and Guidelines Applicable to Disulfoton

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2002
WHO | Air quality guidelines | No data | WHO 2012
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | | EPA 2018a
EPA | DWEL | | EPA 2018a
EPA | Lifetime health advisory | | EPA 2018a
EPA | 10^-4^ Cancer risk | | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009a
EPA | RfD | 4x10^-5^ mg/kg/day^a^ | IRIS 2002
EPA | Chronic dietary PAD | 1.3x10^-4^ mg/kg/day | EPA 2006
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances added to food | Not listed | FDA 2021a
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | Group E^b^ | EPA 2021
IARC | Carcinogenicity classification | No data | IARC 2021
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | No data | OSHA 2021a, 2021b, 2022
NIOSH | REL (up to 10-hour TWA) | 0.1 mg/m^3^ ^c^ | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018e
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^d^ | 0.18 mg/m^3^ | DOE 2018a
DOE | PAC-2^d^ | 2 mg/m^3^ | DOE 2018a
DOE | PAC-3^d^ | 8.8 mg/m^3^ | DOE 2018a
Miscellaneous Federal Guidelines
EPA | Cancelled for use in pesticides | Cancelled | EPA 2010

a Based on the LOAEL of 0.04 mg/kg/day for decreased acetylcholinesterase activity in rat pups in a multigenerational feeding study in rats (Hixson and Hathaway 1986).

b Group E: evidence of noncarcinogenicity for humans.

c With skin designation, indicating the potential for dermal absorption.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; HHS = Department of Health and Human Services; DOE = Department of Energy; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PAD = Population Adjusted Dose; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization