# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Disulfoton is a systemic insecticide/acaricide that belongs to the organophosphate class of pesticides. Disulfoton does not occur naturally. Table 4-1 lists common synonyms, trade names, and other pertinent identification information for disulfoton.

Table 4-1 Chemical Identity of Disulfoton

Characteristic | Information | Reference
Chemical name | Disulfoton | NLM 2021
Synonym(s) and Registered trade name(s) | o,o-Diethyl s-(2-eththioethyl) phosphorodithioate; Ethylthiodemeton; M-74; thiodemeton; Di-Syston; Dithiosystox; Solvirex; ENT 23347; Frumin AL | NLM 2021
Chemical formula | C_8_H_19_O_2_PS_3_ | Lide 2005
Chemical structure | Chemical structure | NLM 2021
CAS registry number | 298-04-4 | Lide 2005
EPA hazardous waste | P039 | EPA 2019a

CAS = Chemical Abstracts Service; EPA = Environmental Protection Agency; NLM = National Library of Medicine; UNII = Unique Ingredient Identifier

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Pure disulfoton is a colorless oil with low volatility and water solubility, but is readily soluble in most organic solvents and fatty oils (Bowman and Sans 1983; EPA 1978). The half-life of disulfoton suggests that it is short-lived in the atmosphere. Table 4-2 lists important physical and chemical properties of disulfoton.

Table 4-2 Physical and Chemical Properties of Disulfoton

Property | Information | Reference
Molecular weight | 274.405 g/mol | Lide 2005
Color | Colorless to yellow | Sanborn et al. 1977
Physical state | Liquid | Muir et al. 2004
Melting point(s) | -25.0°C | Lide 2005
Boiling point(s) | 108°C at 0.01 mm Hg; 128°C at 1.0 mm Hg | Lide 2005
Density:; at 20°C | 1.144 g/cm^3^ | Lide 2005
Odor | Sulfur | NLM 2021
Odor threshold: | | NLM 2021
Water | No data
Air | No data
Solubility:
Water at 20°C | 25 mg/L | NLM 2021
Organic solvent(s) | Readily soluble in most | EPA 1978
Partition coefficients:
Log K_ow_ | 4.02 | NIOSH 2017
Log K_oc_ | 3.2–3.3 | Wauchope et al. 2002
Vapor pressure at 25°C | 9.75x10^-5^ mm Hg | NLM 2021
Henry’s law constant at 25°C | 2.2x10^-6^ atm-m^3^/mol | NLM 2021
Degradation half-life in air via reaction with OH radicals | ≈3 hours | Meylan and Howard 1993
Dissociation constant | No data | NLM 2021
Heat of vaporization | 76.7 kJ/mol at 25°C | NIST 2018
Autoignition temperature | No data | NLM 2021
Flashpoint | >180°F (>82°C) | NIOSH 2018
Flammability limits in air | No data | NIOSH 2018
Conversion factors | 1 ppm=11.22 mg/m^3^; 1 mg/m^3^=0.089 ppm | ACGIH 2002