# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR DISULFOTON

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to disulfoton, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to disulfoton:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to disulfoton. The inclusion criteria used to identify relevant studies examining the health effects of disulfoton are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; - Human; - Laboratory mammals
Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of disulfoton. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for disulfoton released for public comment in 2021. See Appendix B for the databases searched and the search strategy.

A total of 98 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of disulfoton.

Title and Abstract Screen. In the Title and Abstract Screen step, 98 records were reviewed; 1 document was considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those documents, 112 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for disulfoton and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels of Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for disulfoton identified in human and animal studies are presented in Tables C-3 and C-4, respectively.

Human studies evaluating noncancerous effects are primarily case reports of accidental or intentional exposure, and few epidemiological studies on occupational exposure that have examined a limited number of health endpoints. However, these studies substantially indicate that the neurological system is most susceptible to disulfoton toxicity. Animal studies have examined a wide range of potential endpoints following oral exposure, while inhalation studies were limited to intermediate studies of neurotoxicity and a broad range of systemic effects. Dermal studies were limited to examining acute lethality, neurological outcomes, and varying systemic effects. Neurological effects, including developmental neurotoxicity, is considered the most sensitive outcome, as the effects seen at low inhalation concentrations and oral doses were used in deriving inhalation and oral MRLs. Studies examining the neurological endpoints were carried through Steps 4–8 of the systematic review. There were 112 studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Disulfoton Evaluated in Human Studies

| Body Weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation Studies
Cohort | 0 | 2 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 2
Cohort | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Oral Studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0
Case series | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0
Dermal Studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-4 Overview of the Health Outcomes for Disulfoton Evaluated in Experimental Animal Studies

| Body Weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation Studies
Acute-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0
Acute-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0
Intermediate-duration | 3 | 2 | 2 | 2 | 2 | 1 | 2 | 2 | 1 | 2 | 2 | 2 | 3 | 2 | 0 | 0 | 1
Intermediate-duration | 1 | 2 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 2 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Oral Studies
Acute-duration | 10 | 1 | 0 | 1 | 0 | 0 | 3 | 0 | 0 | 1 | 4 | 1 | 21 | 3 | 4 | 0 | 0
Acute-duration | 9 | 1 | 0 | 1 | 0 | 0 | 3 | 0 | 0 | 0 | 4 | 1 | 21 | 2 | 4 | 0 | 0
Intermediate-duration | 9 | 3 | 3 | 2 | 2 | 4 | 2 | 4 | 1 | 4 | 2 | 2 | 14 | 4 | 3 | 0 | 0
Intermediate-duration | 8 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 14 | 1 | 3 | 0 | 0
Chronic-duration | 3 | 2 | 3 | 4 | 5 | 6 | 4 | 4 | 3 | 7 | 4 | 4 | 7 | 4 | 0 | 0 | 4
Chronic-duration | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 2 | 1 | 4 | 2 | 1 | 7 | 1 | 0 | 0 | 0
Dermal Studies
Acute-duration | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0
Acute-duration | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0
Intermediate-duration | 2 | 2 | 1 | 2 | 2 | 0 | 1 | 1 | 2 | 0 | 1 | 1 | 2 | 1 | 0 | 0 | 0
Intermediate-duration | 1 | 2 | 0 | 2 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 2 | 1 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

* Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; - Were the comparison groups appropriate?
Confounding bias; - Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational epidemiological studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational epidemiological studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of disulfoton health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Disulfoton—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?* | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?* | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Neurological effects
Cohort studies
Brokopp et al. 1981 | + | − | + | ++ | + | ++ | First
Gómez-Arroyo et al. 2000 | + | + | + | + | + | ++ | First
Wolfe et al. 1978 | − | − | − | + | + | + | Third
Case studies
Futagami et al. 1995 | NA | + | NA | − | ++ | ++ | Second
Hattori et al. 1982 | NA | + | NA | ++ | ++ | ++ | First
Savage et al. 1971 | NA | + | NA | + | + | + | First
Yashiki et al. 1990 | NA | + | NA | ++ | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

Table C-9 Risk of Bias Assessment for Select Endpoints for Disulfoton–Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Developmental effects
Oral acute exposure
Lamb and Hixson 1983 (rats) | ++ | + | + | + | + | + | + | ++ | First
Tesh et al. 1982 (rabbits) | + | + | + | + | − | + | + | + | First
Oral intermediate exposure
Hixson and Hathaway 1986 (rats) | ++ | + | ++ | + | ++ | + | + | ++ | First
Klaus 2006c (rats) | + | + | + | + | ++ | + | + | ++ | First
Ryan et al. 1970 (rats) | − | + | − | + | − | − | − | + | Third
Sheets 2005 (rats) | ++ | ++ | + | + | + | + | ++ | ++ | First
Taylor 1965a (rats) | − | − | + | + | + | + | + | − | Second
Outcome: Neurological effects
Inhalation acute exposure
Doull 1957 (mice) | + | + | + | − | − | + | + | ++ | First
Doull 1957 (rats) | + | + | + | − | − | + | + | ++ | First
DuBois and Kinoshita 1971 (rats) | − | + | + | − | + | + | + | ++ | First
Thyssen 1978 (rats) | + | − | + | − | + | + | ++ | ++ | First
Inhalation intermediate exposure
Shiotsuka 1988 (rats) | ++ | + | ++ | + | + | + | + | ++ | First
Shiotsuka 1989 (rats) | ++ | + | ++ | − | + | + | + | ++ | First
Thyssen 1980 (rats) | ++ | + | + | − | + | + | + | ++ | First
Thyssen 1980 (rats) | + | + | + | − | + | + | + | ++ | First
Oral acute exposure
Costa and Murphy 1983a (rats) | − | + | + | + | − | + | + | + | First
Costa et al. 1984 (rats) | − | + | + | + | − | + | + | ++ | First
Costa et al. 1986 (rats) | − | + | + | + | − | + | + | + | First
Costa et al. 1986(rats) | − | + | + | + | − | + | + | + | First
Crawford and Anderson 1974 (rats) | − | − | − | + | + | − | + | + | Third
Fitzgerald and Costa 1992 (rats) | + | − | + | + | + | + | + | ++ | First
Fitzgerald and Costa 1993 (rats) | ++ | + | + | + | + | + | + | ++ | First
Klaus 2006a (rats) | ++ | + | + | + | ++ | + | + | ++ | First
Klaus 2006b (rats) | + | + | − | + | − | + | + | ++ | First
Lamb and Hixson 1983 (rats) | ++ | + | + | + | + | + | + | ++ | First
EPA 2007 (rats) | ++ | + | + | + | ++ | + | + | ++ | First
EPA 2007 (rats) | ++ | + | + | + | ++ | + | + | ++ | First
EPA 2007 (rats) | ++ | + | + | + | ++ | + | + | ++ | First
EPA 2007 (rats) | ++ | + | + | + | ++ | + | + | ++ | First
Matsuda et al. 2000 (rats) | − | + | + | + | + | + | + | ++ | First
Mihail 1978 (mice) | − − | + | + | + | − | + | + | + | First
Mihail 1978 (rats) | − − | + | + | + | − | + | + | ++ | First
Mihail 1978 (Beagle dogs) | − − | + | + | + | − | + | + | + | First
Pawar and Fawade 1978 (rats) | − | + | + | + | + | + | + | ++ | First
Schwab and Murphy 1981 (rats) | + | + | ++ | + | + | + | + | ++ | First
Schwab et al. 1983 (rats) | − | + | + | + | + | + | + | + | First
Sheets 1993a (rats) | ++ | ++ | ++ | + | + | + | ++ | ++ | First
Su et al. 1971 (rats) | + | + | + | + | − | + | + | + | First
Yagle and Costa 1996 (rats) | − | + | + | − | + | + | + | ++ | First
Oral intermediate exposure
Christenson and Wahle 1993 (rat) | ++ | + | ++ | − | + | ++ | + | ++ | First
Clark and Pearson 1973 (rats) | + | + | + | + | + | + | + | + | First
Clark and Stavinoha 1971 (mice) | − | − | − | − | − | + | − | + | Third
Clark and Stavinoha 1971 (rats) | − | − | − | − | − | + | − | + | Third
Clark et al. 1971 (mice) | + | + | + | + | + | + | + | ++ | First
Hayes 1985 (rats) | + | ++ | ++ | + | ++ | + | + | ++ | First
Hikita et al. 1973 (Beagle dogs) | − | − | + | + | + | + | + | ++ | First
Hixson and Hathaway 1986 (rats) | ++ | + | ++ | + | ++ | + | + | ++ | First
Hoffman and Welscher 1975 (Beagle dogs) | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Klaus 2006c (rats) | + | + | + | + | ++ | + | + | ++ | First
Klotzsche 1972 (rats) | − | − | + | + | + | + | + | ++ | First
Rivett et al. 1972 (rats) | ++ | + | ++ | + | + | + | + | ++ | First
Robinson et al. 1978 (rats) | + | + | + | + | + | − | + | ++ | First
Ryan et al. 1970 (rats) | − | + | − | + | − | − | − | + | Third
Schwab and Murphy 1981 (rats) | + | + | + | + | + | + | + | ++ | First
Sheets 1993b (rats) | ++ | ++ | + | ++ | ++ | ++ | ++ | ++ | First
Sheets 2005 (rats) | + | + | + | + | ++ | ++ | + | ++ | First
Stavinoha et al. 1969 (rats) | − | + | − | − | + | + | + | ++ | Second
Oral chronic exposure
Carpy et al. 1975 (rats) | + | + | + | + | + | + | + | ++ | First
Hayes 1983 (mice) | ++ | ++ | ++ | + | + | ++ | + | ++ | First
Hayes 1985 (rats) | + | ++ | ++ | + | ++ | + | + | ++ | First
Hoffman and Welscher 1975 (Beagle dogs) | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Jones et al. 1999 (Beagle dogs) | ++ | + | + | − | + | + | + | ++ | First
Uga et al. 1977 (Beagle dogs) | − | − | + | − | + | + | + | ++ | First
Dermal acute exposure
Croutch and Sheets 2000 (rats) | ++ | + | + | + | + | + | + | ++ | First
Flucke 1986 (rabbits) | ++ | + | + | + | + | + | + | ++ | First
Dermal intermediate exposure
Flucke 1986 (rabbits) | ++ | + | + | + | + | + | + | ++ | First
Flucke 1988 (rabbits) | ++ | + | + | + | + | + | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to disulfoton and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study, observation epidemiology, human-controlled exposures and experimental animals. Unless there was a clear need for delineation in the confidence for a particular outcome, confidence assessments were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to disulfoton and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key study design features was determined for individual studies using four “yes or no” questions which were customized for observational epidemiology, human-controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human-controlled exposure studies, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Human-Controlled Exposure Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining neurologic effects observed in observational epidemiology and animal experimental studies are presented in Tables Table C-13 and Table C-14, respectively.

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-16.

Table C-13 Presence of Key Features of Study Design for Disulfoton—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled Exposure | Exposure prior to outcome | Outcome assess on individual level | Comparison group | Initial study confidence
Outcome: Neurological effects
Cohort studies
Brokopp et al. 1981 | Yes | No | Yes | Yes | Moderate
Gómez-Arroyo et al. 2000 | Yes | Yes | Yes | Yes | High
Wolfe et al. 1978 | Yes | Yes | Yes | No | Moderate
Case studies
Futagami et al. 1995 | NA | NA | Yes | Yes | Low
Hattori et al. 1982 | NA | NA | Yes | Yes | Low
Savage et al. 1971 | NA | NA | Yes | No | Low
Yashiki et al. 1990 | NA | NA | Yes | Yes | Low

NA = Not applicable

Table C-14 Presence of Key Features of Study Design for Disulfoton–Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent Control Group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Developmental
Oral acute exposure
Lamb and Hixson (rats) | Yes | Yes | Yes | Yes | High
Tesh et al. 1982 (rabbits) | No | Yes | Yes | Yes | Moderate
Oral intermediate exposure
Hixson and Hathaway 1986 (rats) | Yes | Yes | Yes | Yes | High
Klaus 2006c (rats) | Yes | Yes | Yes | Yes | High
Ryan et al. 1970 (rats) | Yes | Yes | Yes | No | Moderate
Sheets 2005 (rats) | Yes | Yes | Yes | Yes | High
Taylor 1965a (rats) | Yes | Yes | Yes | Yes | High
Outcome: Neurologic
Inhalation acute exposure
Doull 1957 (mice) | No | Yes | Yes | Yes | Moderate
Doull 1957 (rats) | No | Yes | Yes | Yes | Moderate
DuBois and Kinoshita 1971 (rats) | Yes | Yes | Yes | No | Moderate
Thyssen 1978 (rats) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Shiotsuka 1988 (rats) | Yes | Yes | Yes | Yes | High
Shiotsuka 1989 (rats) | Yes | Yes | Yes | Yes | High
Thyssen 1980 (rats) | Yes | Yes | Yes | Yes | High
Thyssen 1980 (rats) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Costa and Murphy 1983a (rats) | Yes | No | Yes | Yes | Moderate
Costa et al. 1984 (rats) | Yes | No | Yes | Yes | Moderate
Costa et al. 1986 (rats) | Yes | No | Yes | Yes | Moderate
Crawford and Anderson 1974 (rats) | No | Yes | Yes | No | Low
Fitzgerald and Costa 1992 (rats) | Yes | Yes | Yes | Yes | High
Fitzgerald and Costa 1993 (rats) | Yes | Yes | Yes | Yes | High
Klaus 2006a (rats) | Yes | Yes | Yes | Yes | High
Klaus 2006b (rats) | Yes | Yes | Yes | Yes | High
Lamb and Hixson 1983 (rats) | Yes | Yes | Yes | Yes | High
EPA 2007 (rats) | Yes | Yes | Yes | Yes | High
EPA 2007 (rats) | Yes | Yes | Yes | Yes | High
EPA 2007 (rats) | Yes | Yes | Yes | Yes | High
EPA 2007 (rats) | Yes | Yes | Yes | Yes | High
Matsuda et al. 2000 (rats) | yes | No | Yes | No | Low
Mihail 1978 (Beagle dogs) | No | No | Yes | Yes | Low
Mihail 1978 (mice) | No | No | Yes | Yes | Low
Mihail 1978 (rats) | No | No | Yes | Yes | Low
Pawar and Fawade 1978 (rats) | Yes | Yes | Yes | Yes | High
Schwab and Murphy 1981 (rats) | Yes | Yes | Yes | Yes | High
Schwab et al. 1983 (rats) | Yes | Yes | Yes | Yes | High
Sheets 1993a (rats) | Yes | Yes | Yes | Yes | High
Su et al. 1971 (rats) | Yes | No | Yes | No | Low
Yagle and Costa 1996 (rats) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Christenson and Wahle 1993 (rat) | Yes | Yes | Yes | Yes | High
Clark and Pearson 1973 | Yes | Yes | No | Yes | Moderate
Clark and Stavinoha 1971 (mice) | Yes | No | Yes | No | Low
Clark and Stavinoha 1971 (rats) | Yes | No | Yes | No | Low
Clark et al. 1971 (mice) | Yes | Yes | Yes | Yes | High
Hayes 1985 (rats) | Yes | Yes | Yes | Yes | High
Hikita et al. 1973 (dog) | Yes | No | Yes | Yes | Moderate
Hixson and Hathaway 1986 (rats) | Yes | Yes | Yes | Yes | High
Hoffman and Welscher 1975 (dogs) | Yes | No | Yes | Yes | Moderate
Klaus 2006c (rats) | Yes | Yes | Yes | Yes | High
Klotzsche 1972 (rats) | Yes | Yes | Yes | Yes | High
Rivett et al. 1972 | Yes | Yes | Yes | Yes | High
Robinson et al. 1978 (rats) | Yes | Yes | Yes | Yes | High
Ryan et al. 1970 (rats) | Yes | Yes | Yes | No | Moderate
Schwab and Murphy 1981 (rats) | Yes | Yes | Yes | Yes | High
Sheets 1993b (rats) | Yes | Yes | Yes | Yes | High
Sheets 2005 (rats) | Yes | Yes | Yes | Yes | High
Stavinoha et al. 1969 (rats) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Carpy et al. 1975 (rats) | Yes | Yes | Yes | Yes | High
Hayes 1983 (mice) | Yes | Yes | Yes | Yes | High
Hayes 1985 (rats) | Yes | Yes | Yes | Yes | High
Hoffman and Welscher 1975 (beagle dogs) | Yes | No | Yes | Yes | Moderate
Jones et al. 1999 (beagle dogs) | Yes | No | Yes | Yes | Moderate
Uga et al. 1977 (beagle dogs) | Yes | No | Yes | Yes | Moderate
Dermal acute exposure
Croutch and Sheets 2000 (rats) | Yes | Yes | Yes | Yes | High
Flucke 1986 (rabbits) | Yes | Yes | Yes | Yes | High
Dermal intermediate exposure
Flucke 1986 (rabbits) | Yes | No | Yes | Yes | Moderate
Flucke 1988 (rabbits) | Yes | No | Yes | Yes | Moderate

Table C-15 Initial Confidence Rating for Disulfoton Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Developmental Effects
Oral acute exposure
Animal Studies
Lamb and Hixson (rats) | High | High
Tesh et al. 1982 (rabbits) | Moderate | High
Oral intermediate exposure
Animal Studies
Hixson and Hathaway 1986 (rats) | High | High
Klaus 2006c (rats) | High | High
Ryan et al. 1970 (rats) | Moderate | High
Sheets 2005 (rats) | High | High
Taylor 1965a (rats) | High | High
Outcome: Neurological Effects
Inhalation acute exposure
Animal Studies
Doull 1957 (mice) | Moderate | High
Doull 1957 (rats) | Moderate | High
DuBois and Kinoshita 1971 (rats) | Moderate | High
Thyssen 1978 (rats) | High | High
Inhalation intermediate exposure
Human Studies
Wolfe et al. 1978 | Moderate | Moderate
Animal Studies
Shiotsuka 1988 (rats) | High | High
Shiotsuka 1989 (rats) | High | High
Thyssen 1980 (rats) | High | High
Thyssen 1980 (rats) | High | High
Inhalation chronic exposure
Human Studies
Gómez-Arroyo et al. 2000 | High | High
Oral acute exposure
Human Studies
Futagami et al. 1995 | Low | Low
Hattori et al. 1982 | Low | Low
Yashiki et al. 1990 | Low | Low
Animal studies
Costa and Murphy 1983a (rats) | Moderate | High
Costa et al. 1984 (rats) | Low | High
Costa et al. 1986 (rats) | High | High
Crawford and Anderson 1974 (rats) | High | High
Fitzgerald and Costa 1992 (rats) | High | High
Fitzgerald and Costa 1993 (rats) | Low | High
Klaus 2006a (rats) | High | High
Klaus 2006b (rats) | High | High
Lamb and Hixson 1983 (rats) | Low | High
EPA 2007 (rats) | High | High
EPA 2007 (rats) | High | High
EPA 2007 (rats) | High | High
EPA 2007 (rats) | High | High
Matsuda et al. 2000 (rats) | Low | High
Mihail 1978 (Beagle dogs) | Low | High
Mihail 1978 (mice) | High | High
Mihail 1978 (rats) | High | High
Pawar and Fawade 1978 (rats) | High | High
Schwab and Murphy 1981 (rats) | High | High
Schwab et al. 1983 (rats) | Low | High
Sheets 1993a (rats) | High | High
Su et al. 1971 (rats) | Moderate | High
Yagle and Costa 1996 (rats) | Moderate | High
Oral intermediate exposure
Animal studies
Christenson and Wahle 1993 (rat) | High | High
Clark and Pearson 1973 | Moderate | High
Clark and Stavinoha 1971 (mice) | Low | High
Clark and Stavinoha 1971 (rats) | Low | High
Clark et al. 1971 (mice) | High | High
Hayes 1985 (rats) | High | High
Hikita et al. 1973 (dog) | Moderate | High
Hixson and Hathaway 1986 (rats) | High | High
Hoffman and Welscher 1975 (dogs) | Moderate | High
Klaus 2006c (rats) | High | High
Klotzsche 1972 (rats) | High | High
Rivett et al. 1972 | High | High
Robinson et al. 1978 (rats) | High | High
Ryan et al. 1970 (rats) | Moderate | High
Schwab and Murphy 1981 (rats) | High | High
Sheets 1993b (rats) | High | High
Sheets 2005 (rats) | High | High
Stavinoha et al. 1969 (rats) | High | High
Oral chronic exposure
Animal studies
Carpy et al. 1975 (rats) | High | High
Hayes 1983 (mice) | High | High
Hayes 1985 (rats) | High | High
Hoffman and Welscher 1975 (beagle dogs) | Moderate | High
Jones et al. 1999 (beagle dogs) | Moderate | High
Uga et al. 1977 (beagle dogs) | Moderate | High
Dermal acute exposure
Human studies
Savage et al. 1971 | Low | Low
Animal studies
Croutch and Sheets 2000 (rats) | High | High
Flucke 1986 (rabbits) | High | High
Dermal intermediate exposure
Human studies
Wolfe et al. 1978 | Moderate | Moderate
Animal studies
Flucke 1986 (rabbits) | Moderate | Moderate
Flucke 1988 (rabbits) | Moderate | Moderate
Dermal chronic exposure
Human studies
Brokopp et al. 1981 | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for neurological effects are presented in Table C-15. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with disulfoton exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-5, C-6, and C-7). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias).
  Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

The results of this assessment are presented in Table C-16, and the final confidence in the body of literature for the neurological endpoint is presented in Table C-17.

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Developmental effects
Animal studies | High | None | High
Outcome: Neurological effects
Human studies | High | -1 Indirectness – length of time between exposure and outcome assessment | Moderate
Animal studies | High | +1 Consistency in the body of evidence | High

Table C-17 Confidence in the Body of Evidence for Disulfoton

Outcome | Confidence in body of evidence
Outcome | Human Studies | Animal Studies
Developmental effects | No data | High
Neurological effects | Moderate | High

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for disulfoton, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome or very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for disulfoton is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Disulfoton

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human Studies
Developmental effects | No data | | No data
Neurological effects | Moderate | Health Effect | Moderate
Animal Studies
Developmental effects | High | Health Effect | High
Neurological effects | High | Health Effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

○ Not identified to be a hazard in humans
○ Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used.

The hazard identification conclusions for disulfoton are listed below and summarized in Table C-19.

Presumed Health Effects

- Neurological effects following oral exposure.
  ○ Moderate evidence from human case studies (Futagami et al. 1995; Hattori et al. 1982; Yashiki et al. 1990).
  ○ High level of evidence in rats and dogs from acute exposure to disulfoton (Fitzgerald and Costa 1993; Lamb and Hixson 1983; Schwab and Murphy 1981; Sheets 1993a; Yagle and Costa 1996), and intermediate exposure to disulfoton including mice (Clark et al. 1971; Hayes 1985; Hixson and Hathaway 1986; Hoffman and Welscher 1975; Sheets 1993b), and chronic exposure to disulfoton to rats, dogs, and mice (Carpy et al. 1975; Hayes 1983; Hayes 1985; Hoffman and Welscher 1975; Jones et al. 1999).
- Neurological effects following inhalation exposure.
  ○ Low evidence from human studies due to confounding and low number of studies (Gómez-Arroyo et al. 2000; Wolfe et al. 1978).
  ○ High level of evidence in rats and mice from acute exposure to disulfoton (Doull 1957; DuBois and Kinoshita 1971; Thyssen 1978), and intermediate exposure to disulfoton in rats (Shiotsuka 1988, 1989; Thyssen 1980).
- Developmental effects following oral exposure.
  ○ No studies in humans examined developmental effects.
  ○ High level of evidence in rats and rabbits from acute exposure to disulfoton (Lamb and Hixson 1983; Tesh et al. 1982), and intermediate exposure to disulfoton in rats (Hixson and Hathaway 1986; Klaus 2006c; Ryan et al. 1970; Sheets 2005; Taylor 1965a).

Not Classifiable Health Effects

- Neurological effects following dermal exposure.
  ○ Low evidence from human studies (Brokopp et al. 1981; Savage et al. 1971; Wolfe et al. 1978).
  ○ Low level of evidence in rabbit from acute and intermediate exposure to disulfoton (Flucke 1986).
- Developmental effects following inhalation or dermal exposure.
  ○ No studies in human or animals examined developmental effects following inhalation or dermal exposure to disulfoton.

Table C-19 Hazard Identification Conclusions for Disulfoton

Outcome | Hazard identification
Developmental effects | Presumed health effect following oral exposure; Not classifiable (inhalation and dermal exposure)
Neurological effects | Presumed health effect following inhalation and oral exposure; Not classifiable (dermal exposure)