# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR DISULFOTON

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to disulfoton.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for disulfoton. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of disulfoton have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of disulfoton are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer; - Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for disulfoton released for public comment in 2021; thus, the literature search was restricted to studies published between January 2021 and November 2021. The following main databases were searched in November 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for disulfoton. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to disulfoton were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
11/2021 | (“Disulfoton”[mh] OR “BAY 19639”[tw] OR “Bayer 19639”[tw] OR “Di-syston”[tw] OR “Di-Syston 8”[tw] OR “Di-Syston G”[tw] OR “Disulfoton”[tw] OR “Dithiodemeton”[tw] OR “Dithiosystox”[tw] OR “Dution”[tw] OR “Ekatin TD”[tw] OR “Ekatine”[tw] OR “Ethyl thiometon”[tw] OR “Ethylthiometon B”[tw] OR “Frumin”[tw] OR “Glebofos”[tw] OR “Insyst-D”[tw] OR “O,O-Diethyl 2-ethylthioethyl phosphorodithioate”[tw] OR “O,O-Diethyl S-(2-(ethylthio)ethyl) dithiophosphate”[tw] OR “O,O-Diethyl S-(2-(ethylthio)ethyl)phosphorodithioate”[tw] OR “O,O-Diethyl S-(2-eththioethyl) phosphorodithioate”[tw] OR “O,O-Diethyl S-(2-eththioethyl) thiothionophosphate”[tw] OR “O,O-Diethyl S-(2-ethylmercaptoethyl) dithiophosphate”[tw] OR “O,O-Diethyl S-2-(ethylthio)ethyl phosphorodithioate”[tw] OR “O,O-Diethyl S-[2-(ethylsulfanyl)ethyl] phosphorodithioate”[tw] OR “O,O-Diethyl S-[2-(ethylthio)ethyl] dithiophosphate”[tw] OR “O,O-Diethyl S-[2-(ethylthio)ethyl] phosphorodithioate”[tw] OR “O,O-Diethyl-S-ethylmercapto-ethyl dithiophosphate”[tw] OR “Phosphorodithioic acid, O,O-diethyl S-(2-(ethylthio)ethyl) ester”[tw] OR “Phosphorodithioic acid, O,O-diethyl S-[2-(ethylthio)ethyl] ester”[tw] OR “Phosphorodithioic acid, O,O-diethylS-[2-(ethylthio)ethyl] ester”[tw] OR “S 276”[tw] OR “S-2-(Ethylthio)ethyl O,O-diethyl ester of phosphorodithioic acid”[tw] OR “Solvigran”[tw] OR “Solvirex”[tw] OR “Thiodemeton”[tw] OR “Vuagt 1-4”[tw] OR “Vuagt 1964”[tw] OR ((“m 74”[tw] OR “m 74”[tw]) AND pesticide)) AND (2018/01/01:3000[dp] OR 2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat]); (“Demeton”[tw] OR “Di Syston”[tw] OR “Dimaz”[tw] OR “Disulfaton”[tw] OR “Disyston”[tw] OR “Disystox”[tw] OR “Ethylthiodemeton”[tw] OR “O,O-DIETHYL S-(2-(ETHYLTHIO)ETHYL)) DITHIOPHOSPHATE”[tw] OR “O,O-Diethyl S-2-ethylthioethyl phosphorodithioate”[tw] OR “O,O-diethyl-S-ethylmercapto-ethyl dithiophosphate”[tw] OR “O,O-ETHYL S-2(ETHYLTHIO)ETHYL PHOSPHORODITHIOATE”[tw] OR “O,O-DIETHYL S-(2-ETHTHIOETHYL) THIOTHIONOPHOSPHATE”[tw] OR “Phosphorodithioic acid O,O-diethyl S-[2-(ethylthio)ethyl] ester”[tw] OR “PHOSPHORODITHIONIC ACID, S2-(ETHYLTHIO)ETHYL-O,O-DIETHYL ESTER”[tw]) AND (2018/01/01:3000[dp] OR 2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat])
NTRL
11/2021 | Limited 2018-present; - Di-syston; - Disulfoton; - Dithiodemeton; - Dithiosystox; - Dution; - Ethyl thiometon; - Ethylthiometon B; - O,O-Diethyl 2-ethylthioethyl phosphorodithioate; - O,O-Diethyl S-(2-(ethylthio)ethyl) dithiophosphate; - O,O-Diethyl S-(2-(ethylthio)ethyl)phosphorodithioate; - O,O-Diethyl S-(2-eththioethyl) phosphorodithioate; - O,O-Diethyl S-(2-eththioethyl) thiothionophosphate; - O,O-Diethyl S-(2-ethylmercaptoethyl) dithiophosphate; - O,O-Diethyl S-2-(ethylthio)ethyl phosphorodithioate; - O,O-Diethyl S-[2-(ethylsulfanyl)ethyl] phosphorodithioate; - O,O-Diethyl S-[2-(ethylthio)ethyl] dithiophosphate; - O,O-Diethyl S-[2-(ethylthio)ethyl] phosphorodithioate; - O,O-Diethyl-S-ethylmercapto-ethyl dithiophosphate; - S-2-(Ethylthio)ethyl O,O-diethyl ester of phosphorodithioic acid; - Solvigran; - Solvirex; - Thiodemeton; - Demeton; - Di Syston; - Disyston; - Disystox; - Ethylthiodemeton; - O,O-DIETHYL S-(2-(ETHYLTHIO)ETHYL)) DITHIOPHOSPHATE; - O,O-Diethyl S-2-ethylthioethyl phosphorodithioate; - O,O-diethyl-S-ethylmercapto-ethyl dithiophosphate; - O,O-ETHYL S-2(ETHYLTHIO)ETHYL PHOSPHORODITHIOATE; - O,O-DIETHYL S-(2-ETHTHIOETHYL) THIOTHIONOPHOSPHATE; - Phosphorodithioic acid O,O-diethyl S-[2-(ethylthio)ethyl] ester; - PHOSPHORODITHIONIC ACID, S2-(ETHYLTHIO)ETHYL-O,O-DIETHYL ESTER
Toxcenter
11/2021 | FILE ‘TOXCENTER’ ENTERED AT 15:28:18 ON 23 NOV 2021; CHARGED TO COST=EH038.13.06.LB.04; L1 2702 SEA FILE=TOXCENTER 298-04-4; L2 2700 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 2441 SEA FILE=TOXCENTER L2 NOT PATENT/DT L4 99 SEA FILE=TOXCENTER L3 AND PY>2017 ACT TOXQUERY/Q; -------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L35 QUE L33 OR L34; -------; L36 66 SEA FILE=TOXCENTER L4 AND L35; L37 2 SEA FILE=TOXCENTER L36 AND MEDLINE/FS; L38 65 DUP REM L36 (1 DUPLICATE REMOVED); ANSWERS ‘1-65’ FROM FILE TOXCENTER D SCAN L38

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
11/2021 | Compound searched: 298-04-4
NTP
11/2021 | 298-04-4; “Di-syston” “Disulfoton” “Dithiodemeton” “Dithiosystox”; “Dution” “Ethyl thiometon” “Ethylthiometon B” “O,O-Diethyl 2-ethylthioethyl phosphorodithioate”; “O,O-Diethyl S-(2-(ethylthio)ethyl) dithiophosphate” “O,O-Diethyl S-(2-(ethylthio)ethyl)phosphorodithioate” “O,O-Diethyl S-(2-eththioethyl) phosphorodithioate” “O,O-Diethyl S-(2-eththioethyl) thiothionophosphate”; “O,O-Diethyl S-(2-ethylmercaptoethyl) dithiophosphate” “O,O-Diethyl S-2-(ethylthio)ethyl phosphorodithioate” “O,O-Diethyl S-[2-(ethylsulfanyl)ethyl] phosphorodithioate” “O,O-Diethyl S-[2-(ethylthio)ethyl] dithiophosphate”; “O,O-Diethyl S-[2-(ethylthio)ethyl] phosphorodithioate” “O,O-Diethyl-S-ethylmercapto-ethyl dithiophosphate” “S-2-(Ethylthio)ethyl O,O-diethyl ester of phosphorodithioic acid” “Solvigran”; “Solvirex” “Thiodemeton” “Demeton” “Di Syston”; “Disyston” “Disystox” “Ethylthiodemeton” “O,O-DIETHYL S-(2-(ETHYLTHIO)ETHYL)) DITHIOPHOSPHATE”; “O,O-Diethyl S-2-ethylthioethyl phosphorodithioate” “O,O-diethyl-S-ethylmercapto-ethyl dithiophosphate” “O,O-ETHYL S-2(ETHYLTHIO)ETHYL PHOSPHORODITHIOATE” “O,O-DIETHYL S-(2-ETHTHIOETHYL) THIOTHIONOPHOSPHATE”; “Phosphorodithioic acid O,O-diethyl S-[2-(ethylthio)ethyl] ester”; “PHOSPHORODITHIONIC ACID, S2-(ETHYLTHIO)ETHYL-O,O-DIETHYL ESTER”
Regulations.gov
11/2021 | 298-04-4; “Di-syston”; “Disulfoton”; “Dithiodemeton”; “Dithiosystox”; “Dution”; “Ethyl thiometon”; “Ethylthiometon B”; “O,O-Diethyl 2-ethylthioethyl phosphorodithioate”; “O,O-Diethyl S-(2-(ethylthio)ethyl) dithiophosphate”; “O,O-Diethyl S-(2-(ethylthio)ethyl)phosphorodithioate”; “O,O-Diethyl S-(2-eththioethyl) phosphorodithioate”; “O,O-Diethyl S-(2-eththioethyl) thiothionophosphate”; “O,O-Diethyl S-(2-ethylmercaptoethyl) dithiophosphate”; “O,O-Diethyl S-2-(ethylthio)ethyl phosphorodithioate”; “O,O-Diethyl S-[2-(ethylsulfanyl)ethyl] phosphorodithioate”; “O,O-Diethyl S-[2-(ethylthio)ethyl] dithiophosphate”; “O,O-Diethyl S-[2-(ethylthio)ethyl] phosphorodithioate”; “O,O-Diethyl-S-ethylmercapto-ethyl dithiophosphate”; “S-2-(Ethylthio)ethyl O,O-diethyl ester of phosphorodithioic acid”; “Solvigran”; “Solvirex”; “Thiodemeton”; “Demeton”; “Di Syston”; “Disyston”; “Disystox”; “Ethylthiodemeton”; “O,O-DIETHYL S-(2-(ETHYLTHIO)ETHYL)) DITHIOPHOSPHATE”; “O,O-Diethyl S-2-ethylthioethyl phosphorodithioate”; “O,O-diethyl-S-ethylmercapto-ethyl dithiophosphate”; “O,O-ETHYL S-2(ETHYLTHIO)ETHYL PHOSPHORODITHIOATE”; “O,O-DIETHYL S-(2-ETHTHIOETHYL) THIOTHIONOPHOSPHATE”; “Phosphorodithioic acid O,O-diethyl S-[2-(ethylthio)ethyl] ester”; “PHOSPHORODITHIONIC ACID, S2-(ETHYLTHIO)ETHYL-O,O-DIETHYL ESTER”
NIH RePORTER
12/2021 | Search Criteria Fiscal Year: Active ProjectsText Search: “BAY 19639” OR “Bayer 19639” OR “Di-syston” OR “Disulfoton” OR “Dithiodemeton” OR “Dithiosystox” OR “Dution” OR “Ekatin TD” OR “Ekatine” OR “Ethyl thiometon” OR “Ethylthiometon B” OR “Frumin” OR “Glebofos” OR “Insyst-D” OR “O,O-Diethyl 2-ethylthioethyl phosphorodithioate” OR “O,O-Diethyl S-(2-(ethylthio)ethyl) dithiophosphate” OR “O,O-Diethyl S-(2-(ethylthio)ethyl)phosphorodithioate” OR “O,O-Diethyl S-(2-eththioethyl) phosphorodithioate” OR “O,O-Diethyl S-(2-eththioethyl) thiothionophosphate” OR “O,O-Diethyl S-(2-ethylmercaptoethyl) dithiophosphate” OR “O,O-Diethyl S-2-(ethylthio)ethyl phosphorodithioate” OR “O,O-Diethyl S-[2-(ethylsulfanyl)ethyl] phosphorodithioate” OR “O,O-Diethyl S-[2-(ethylthio)ethyl] dithiophosphate” OR “O,O-Diethyl S-[2-(ethylthio)ethyl] phosphorodithioate” OR “O,O-Diethyl-S-ethylmercapto-ethyl dithiophosphate” OR “Phosphorodithioic acid, O,O-diethyl S-(2-(ethylthio)ethyl) ester” OR “Phosphorodithioic acid, O,O-diethyl S-[2-(ethylthio)ethyl] ester” OR “Phosphorodithioic acid, O,O-diethylS-[2-(ethylthio)ethyl] ester” OR “S 276” OR “S-2-(Ethylthio)ethyl O,O-diethyl ester of phosphorodithioic acid” OR “Solvigran” OR “Solvirex” OR “Thiodemeton” OR “Vuagt 1-4” OR “Vuagt 1964” OR “Demeton” OR “Di Syston” OR “Dimaz” OR “Disulfaton” OR “Disyston” OR “Disystox” OR “Ethylthiodemeton” OR “O,O-DIETHYL S-(2-(ETHYLTHIO)ETHYL)) DITHIOPHOSPHATE” OR “O,O-Diethyl S-2-ethylthioethyl phosphorodithioate” OR “O,O-diethyl-S-ethylmercapto-ethyl dithiophosphate” OR “O,O-ETHYL S-2(ETHYLTHIO)ETHYL PHOSPHORODITHIOATE” OR “O,O-DIETHYL S-(2-ETHTHIOETHYL) THIOTHIONOPHOSPHATE” OR “Phosphorodithioic acid O,O-diethyl S-[2-(ethylthio)ethyl] ester” OR “PHOSPHORODITHIONIC ACID, S2-(ETHYLTHIO)ETHYL-O,O-DIETHYL ESTER” (advanced)Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 76
- Number of records identified from other strategies: 22
- Total number of records to undergo literature screening: 98

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on disulfoton:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 98
- Number of studies considered relevant and moved to the next step: 32

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 32
- Number of studies cited in the pre-public draft of the toxicological profile: 353
- Total number of studies cited in the profile: 328

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2021 Literature Search Results and Screen for Disulfoton

Figure B-1 description