# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: The intermediate-duration inhalation MRL of 0.0006 mg/m^3^ (0.6 µg/m^3^) is adopted as the acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: A limited number of acute-duration inhalation animal studies were available evaluating the toxicity of disulfoton. These studies primarily evaluated neurological effects (Doull 1957; DuBois and Kinoshita 1971; Thyssen 1978). These studies also evaluated mortality (Doull 1957; Thyssen 1978), and one study evaluated body weight (Thyssen 1978) following acute inhalation exposure to disulfoton.

The available data suggest that neurological toxicity, particularly cholinesterase inhibition, is the most sensitive endpoint following acute-duration inhalation exposure to disulfoton. In human studies, mild depression of red blood cell AChE activity was reported in workers exposed by the inhalation and dermal routes (Wolfe et al. 1978). In an epidemiological study, headaches and nausea were reported by workers exposed to various pesticides including disulfoton (Gómez-Arroyo et al. 2000). Thyssen (1978) evaluated the acute-duration inhalation toxicity of disulfoton in three separate experiments using different durations: a single 1-hour exposure, single 4-hour exposure, or daily 4-hour exposure for 5 days. Exposure concentrations for male rats exposed to single 1-hour exposures were 133, 196, 256, 322, and 660 mg/m^3^; for female rats, the exposure concentrations were 27, 33, 46, 58, 80, and 133 mg/m^3^. For male rats exposed to single 4-hour exposures, exposure concentrations were 34, 48, 51, 64, 78, and 96 mg/m^3^; for female rats, the exposure concentrations were 3.4, 5, 7, 10, 13, and 20 mg/m^3^. For both male and female rats in the five day 4-hour exposure group, the exposure concentrations were 0, 0.5, 1.8, and 9.8 mg/m^3^. These doses were adjusted for intermittent exposure, and are presented with relevant neurological NOAELs and LOAELs in Table A-1. Red blood cell and plasma AChE activity was measured from blood samples taken prior to exposure, and after the 1^st^, 3^rd^, and 5^th^ days of exposure, and 72 hours after exposure termination (Thyssen 1978). At the lowest dose tested, 0.5 mg/m^3^ (NOAEL_ADJ_ 0.083 mg/m^3^), no effects were seen in either sex. Significant inhibition of red blood cell AChE activity and unspecified behavioral disorder symptoms of poisoning were observed at 1.8 mg/m^3^ (LOAEL_ADJ_ 0.3 mg/m^3^) in females. These results are consistent with plasma AChE observations, a more sensitive, but less toxicologically significant, indicator. Similar effects were observed in rats or mice exposed to higher concentrations for shorter durations (Doull 1957; Thyssen 1978). The lowest LOAEL_ADJ_ for an acute-duration study is 1.8 mg/m^3^ (LOAEL_ADJ_ 0.3 mg/m^3^). DuBois and Kinoshita (1971) identified a NOAEL_ADJ_ of 0.029 mg/kg/day for brain AChE inhibition; however, higher doses were not tested to identify a LOAEL within this study.

Table A-1 Summary of Relevant Neurological NOAEL and LOAEL Values of Acute-Duration Inhalation Exposure to Disulfoton

Species (sex) | Frequency/duration | NOAEL (NOAEL_ADJ_) (mg/m^3^) | LOAEL (LOAEL_ADJ_) (mg/m^3^) | Effect | Reference
Wistar rats (F) | 4 hours/day; 5 days | 0.5 (0.083) | 1.8 (0.3) | 26% depression in red blood cell AChE activity; unspecified behavioral disorders, sluggishness, drowsiness | Thyssen 1978
Wistar rats (F) | 4 hours | | 3.4 (0.5667) | Sluggishness, failure to groom, typical signs of cholinesterase inhibition not otherwise described | Thyssen 1978
Wistar rats (F) | 1 hour | | 27 (4.5) | sluggishness, failure to groom, typical signs of cholinesterase inhibition not otherwise described | Thyssen 1978
Holtzman rats F) | 1 hour/ day; days | 5 0.7 (0.029) | | No significant inhibition of brain AChE | DuBois and Kinoshita 1971
Holtzman rats (F) | 1 hour/ day; 10 days | 0.7 (0.029) | | No significant inhibition of brain AChE | DuBois and Kinoshita 1971

AChE = acetylcholinesterase; F = females; LOAEL = lowest-observed-adverse-effect level; LOAEL_ADJ_ = LOAEL adjusted for intermittent exposure; dose was multiplied to represent a continuous 24-hour, 7-day exposure; NOAEL = no-observed-adverse-effect level; NOAEL_ADJ_ = NOAEL adjusted for intermittent exposure; dose was multiplied to represent a continuous 24-hour, 7-day exposure

Among reliable animal study results, the NOAEL_ADJ_ of 0.083 mg/m^3^ for red blood cell AChE depression in female rats exposed via inhalation chamber for 4 hours/day for 5 days represents the most sensitive adverse effects from acute-duration inhalation exposure to disulfoton (Thyssen 1978). Using a NOAEL_ADJ_ of 0.083 mg/m^3^ as the point of departure (POD) and a total uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability) would result in an acute-duration inhalation MRL of 0.003 mg/m^3^. However, this value is not proposed for the acute-duration MRL. ATSDR has instead opted to adopt the intermediate-duration inhalation MRL of 0.0006 mg/m^3^ for the acute-duration MRL. The reasons for this include that Thyssen (1978) used red blood cell AChE as a surrogate for brain AChE. This is common practice when sufficient data on the latter are not available. However, the intermediate-duration inhalation MRL POD is based on brain AChE depression, a stronger indicator of the neurological effects of disulfoton. Additionally, the intermediate-duration MRL study exposed rats to 15 total exposures of disulfoton over a 21-day period and is not substantially longer than the threshold for acute-duration of 14 days. Therefore, the intermediate-duration inhalation MRL of 0.0006 mg/m^3^ for disulfoton is adopted as the acute-duration inhalation MRL because it is protective of acute-duration inhalation exposure to disulfoton.

Agency Contact (Chemical Managers): Melanie Buser, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.0006 mg/m^3^ (0.6 µg/m^3^) or 0.00006 ppm (0.06 ppb)
Critical Effect: | Decreased brain AChE activity
Reference: | Thyssen 1980
Point of Departure: | NOAEL of 0.1 mg/m^3^ (NOAEL_HEC_ of 0.018 mg/m^3^)
Uncertainty Factor: | 30
LSE Graph Key: | 11
Species: | Rats

MRL Summary: An intermediate-duration inhalation MRL of 0.0006 mg/m^3^ (0.6 µg/m^3^) was derived for disulfoton based on inhibition of brain AChE activity in female rats exposed 6 hours/day for 5 days/week for 3 weeks (Thyssen 1980). The MRL is based on a NOAEL of 0.1 mg/m^3^, which was adjusted for intermittent exposure, converted to a human equivalent concentration (HEC) of 0.018 mg/m^3^, and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Toxicity following intermediate inhalation exposure to disulfoton has been examined across multiple endpoints, primarily neurological (Shiotsuka 1988, 1989; Thyssen 1980) and respiratory (Shiotsuka 1989; Thyssen 1980). Other effects of intermediate-inhalation exposure to disulfoton in rats include inflammatory changes in the respiratory tract associated with bone marrow changes at 20.5 mg/m^3^, decreased percentages of lymphocytes with increased polymorphonuclear leukocytes at 3.1 mg/m^3^, increased absolute and relative adrenal weight at 3.1 and 3.7 mg/m^3^ (Thyssen 1980), and increased incidence of inflammation of the nasal turbinates at 1.4 mg/m^3^ (Shiotsuka 1989). The LOAELs and NOAELs (adjusted for intermittent exposure) considered for MRL derivation are presented in Table A-2.

Table A-2 Summary of Relevant Intermediate-Duration Inhalation NOAEL and LOAEL Values for Disulfoton

Species (sex) | Frequency/duration | NOAEL (NOAEL_ADJ_) (mg/m^3^) | LOAEL (LOAEL_ADJ_) (mg/m^3^) | Effect | Reference
Neurological effects
Wistar TNO/W 74 albino rats (M) | 6 hours/day; 5 days/week; 3 weeks | 0.02 (0.0036) | | No depression of red blood cell AChE | Thyssen 1980
Wistar TNO/W 74 albino rats (F) | 6 hours/day; 5 days/week; 3 weeks | 0.02 (0.0036) | 3.1 (0.55) | 3/20 dead | Thyssen 1980
Wistar TNO/W 74 albino rats (M) | 6 hours/day; 5 days/week; 3 weeks | 0.5 (0.089) | 3.7 (0.66) | 24% inhibition of red blood cell AChE, 48% inhibition of brain AChE | Thyssen 1980
Wistar TNO/W 74 albino rats (F) | 6 hours/day; 5 days/week; 3 weeks | 0.1 (0.018) | 0.5 (0.089) | 30% inhibition of brain AChE, lethargy by day 15 | Thyssen 1980
Fischer-344 rats (M) | 6 hour/day, 5 days/week, 13 weeks | 0.16 (0.029) | 1.4 (0.25) | 22–34% inhibition of red blood cell AChE, 28–29% inhibition of brain AChE | Shiotsuka 1989
Respiratory effects
Fischer-344 rats (M, F) | 6 hour/day, 5 days/week, 13 weeks | 0.16 (0.029) | 1.4 (0.25) | 50% increased incidence of inflammation of the nasal turbinates | Shiotsuka 1989

AChE = acetylcholinesterase; F = females; LOAEL = lowest-observed-adverse-effect level; LOAEL_ADJ_ = LOAEL adjusted for intermittent exposure; dose was multiplied to represent a continuous 24-hour, 7-day exposure; M = males; NOAEL = no-observed-adverse-effect level; NOAEL_ADJ_ = NOAEL adjusted for intermittent exposure; dose was multiplied to represent a continuous 24-hour, 7-day exposure

The available data suggest that neurological toxicity, particularly AChE inhibition, is the most sensitive endpoint following intermediate-duration inhalation exposure to disulfoton. In a 13-week study, inhibition of red blood cell and brain AChE activity was observed in rats exposed to 1.4 mg/m^3^, but not 0.16 mg/m^3^ disulfoton 6 hours/day, 5 days/week (Shiotsuka 1989). In male and female rats exposed to disulfoton 6 hours/day for a total of 15 days, inhibition of brain AChE was observed at 0.5 mg/m^3^ (20–30%) accompanied with lethargy, and at 3.7 mg/m^3^ (48–58%) accompanied with muscle tremors, convulsions, increased salivation, and difficulty breathing (Thyssen 1980). The NOAEL of this study was 0.1 mg/m^3^. Thyssen (1980) conducted an additional study using a lower dose to establish a NOAEL of 0.02 mg/m^3^ (NOAEL_ADJ_=0.0036 mg/m^3^) for no change in red blood cell AChE activity in male and female rats (Thyssen 1980). However, the cholinesterase activity of the control group in the second study differed from the primary study.

Selection of the Principal Study: Thyssen (1980) was selected as the principal study. The study conducted two studies evaluating AChE activity in rats, which demonstrated that AChE activity in female rats is sensitive to disulfoton exposure. The first study in Thyssen (1980) identified a NOAEL of 0.1 mg/m^3^ and a LOAEL of 0.5 mg/m^3^ for brain AChE inhibition, lethargy, and behavioral disturbances in female rats. There was not a clear dose-response relationship with either red blood cell or brain AChE inhibition in either sex (see Table A-3). While the second study in Thyssen (1980) identified a lower NOAEL than the first study, there was insufficient support to the toxicological significance of the findings. Only one other dose (3.1 mg/m^3^) was tested in females to determine lethality. Additionally, the brain AChE activity of both sexes in the control group of the second study was 21–28% higher than that of the first study control group. Therefore, results from both studies could not be combined. AChE activity levels from the first Thyssen (1980) study are presented in Table A-3.

Table A-3 Percent Acetylcholinesterase Inhibition in Wistar Rats Exposed to Disulfoton via Inhalation for 15 Days

Dose (mg/m^3^) | Males (n=10/dose) | | Females (n=10/dose)
Dose (mg/m^3^) | Brain u/g (% inhibition) | RBC u/mL (% inhibition) | Brain u/g (% inhibition) | RBC u/mL (% inhibition)
0 (control) | 1.01 | 2.60 | 1.23 | 2.64
0.1 | 0.97 (4%) | 2.61 (−0.4%) | 1.28 (−4%) | 2.50 (5%)
0.5 | 1.21 (−20%) | 2.67 (−3%) | 0.86 (30%) | 2.64 (0%)
3.7 | 0.53 (48%) | 1.98 (24%) | 0.53 (57%) | 1.79 (32%)

RBC = red blood cell

Source: Thyssen 1980

Summary of the Principal Study:

Thyssen JT. 1980. Disulfoton (S 276). The active ingredient of di-syston subacute inhalation study on rats. Wuppertal-Elberfeld, Germany: Bayer AG, Institute of Toxicology. 83-T-80. Bayer Report No. 9065. Mobay ACD Report No. 69361.

Thyssen (1980) conducted two separate 3-week experiments. In the first experiment, male and female Wistar TNO/W 74 albino rats were exposed to concentrations of 0, 0.1, 0.5, or 3.7 mg/m^3^ in an inhalation chamber for 6 hours/day, 5 days/week for 3 weeks, totaling 15 exposures. There were 10 rats/sex/group. Endpoints monitored included body weight, behavior, blood chemistry, clinical signs, histopathology, organ weight, and urinalysis. Red blood cell and plasma AChE activity were measured via blood test prior to the start of the experiment and after the 5^th^, 10^th^, and 15^th^ exposures. Brain AChE was measured after the final exposure. The same methods were applied in the second experiment where 10 male and 10 female rats were exposed to 0 or 0.02 mg/m^3^. Only 20 female rats were exposed to 3.1 mg/m^3^ in order to determine if severe symptoms and mortality seen among females in the first study could be reproduced.

Rats showed concentration-related increased severity of AChE inhibition and cholinergic signs of toxicity. At the lowest exposure level of 0.1 mg/m^3^, no significant changes in AChE activity were seen in either sex; however, lethargy was observed. At 0.5 mg/m^3^, lethargy and failure to groom were observed during the 2^nd^ and 3^rd^ weeks; only significant inhibition of brain AChE was observed in female rats at this dose. At 3.7 mg/m^3^, significant brain and red blood cell AChE inhibition was observed in both sexes, and signs of cholinergic toxicity included muscle tremors, convulsions, and death. A second experiment, using a different control group, was conducted to determine a lower NOAEL of AChE inhibition in rats. No AChE effects or signs of cholinergic toxicity were seen in either sex at 0.02 mg/m^3^. At the exposure level of 3.1 mg/m^3^ in females, the signs of cholinergic toxicity and mortality seen at 3.7 mg/m^3^ in the first experiment were confirmed.

Selection of the Point of Departure for the MRL: Thyssen (1980) identified a NOAEL of 0.1 mg/m^3^ (NOAEL_ADJ_=0.018 mg/m^3^) for AChE inhibition in female rats exposed to disulfoton for 6 hours/day, 5 days/week for 3 weeks. This is supported by the LOAEL of 0.5 mg/m^3^ for brain AChE inhibition and lethargy seen in the same study. The available data in Thyssen (1980) are not amenable to benchmark dose (BMD) modeling as there is not a clear dose-response relationship with AChE inhibition. Therefore, the NOAEL_ADJ_ 0.018 mg/m^3^ was converted to a HEC.

Adjustment for Intermittent Exposure: Given that the exposure in Thyssen (1980) study was intermittent (6 hours/day for 5 days/week), the NOAEL was adjusted for intermittent exposure:

N O A E L_A D J_ = 0.1 m g / m^3^ × (6 h r s)/(24 h r s) × (5 d a y s)/(7 d a y s) = 0.01785 m g / m^3^

Conversion to Human Equivalent Concentration: The NOAEL_ADJ_ was then adjusted to a HEC using the regional gas dose ratio (RGDR_ER_) of 1.0. The methods for derivation of inhalation reference concentrations and application of inhalation dosimetry (EPA 1994) recommends the use of the default RGDR value of 1.0 when the blood:gas partition coefficient (H_b/g_) is unknown.

N O A E L_H E C_ = N O A E L_A D J_ × R G D R_E R_ N O A E L_H E C_ = 0.01785 m g / m^3^ × 1.0 = 0.01785 m g / m^3^

Uncertainty Factor: The NOAEL_HEC,ADJ_ was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

M R L = (N O A E L_H E C_)/(U F s) = (0.01785 m g / m^3^)/(30) = 0.000595 m g / m^3^ ( R o u n d e d t o 0.0006 m g / m^3^ )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Wolfe et al. (1978) estimated mean disulfoton concentrations of 0.06–0.633 mg/m^3^ in air for pesticide-fertilizer mixing operations workers who were exposed for 9 weeks. Among workers with the highest exposures, a 23% inhibition of red blood cell AChE activity was observed with no additional clinical signs. These effects in humans were observed at concentrations 300-fold higher than the MRL.

Agency Contact (Chemical Managers): Melanie Buser, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL due to the lack of toxicity studies for any endpoint. No studies have been found on animal toxicity, and human studies have severe limitations.

Rationale for Not Deriving an MRL: Studies examining toxicity for chronic-duration inhalation of disulfoton are limited to observational human studies that do not provide sufficient toxicity data. Human studies have examined respiratory (Gómez-Arroyo et al. 2000; Hoppin et al. 2017), gastrointestinal, dermal, and neurological effects (Gómez-Arroyo et al. 2000). These studies lacked exposure data, and could not attribute findings solely to disulfoton exposure, as other pesticides were present.

Agency Contact (Chemical Managers): Melanie Buser, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.0003 mg/kg/day (0.3 µg/kg/day)
Critical Effect: | Decreased red blood cell AChE activity
Reference: | Klaus 2006b
Point of Departure: | BMDL_20RD_ of 0.028 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 11
Species: | Rats

MRL Summary: An acute-duration oral MRL of 0.0003 mg/kg/day (0.3 µg/kg/day) was derived for disulfoton based on decreased red blood cell AChE activity in female Wistar rat pups treated with disulfoton for 11 days daily by gavage beginning on PND 11 (Klaus 2006b). The MRL is based on a 20% relative deviation BMDL (BMDL_20RD_) of 0.028 mg/kg/day, which was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Numerous studies have evaluated the oral toxicity of disulfoton following acute-duration exposure across a wide range of endpoints. Neurotoxicity (Costa and Murphy 1983a; Costa et al. 1984, 1986; Crawford and Anderson 1974; EPA 2007; Fitzgerald and Costa 1992, 1993; Klaus 2006a, 2006b; Lamb and Hixson 1983; Matsuda et al. 2000; Mihail 1978; Schwab and Murphy 1981; Pawar and Fawade 1978, 1983; Sheets 1993a; Su et al. 1971; Yagle and Costa 1996), respiratory effects (Mihail 1978), hepatotoxicity (Fawade and Pawar 1978, 1980, 1983), endocrine effects (Brzezinski 1969; Wysocka-Paruszewska 1970, 1971), and developmental toxicity (Lamb and Hixson 1983) have been examined. The LOAELs for these studies range from 0.06 to 5 mg/kg/day; select LOAELs and NOAELs are presented in Table A-4.

Table A-4 Summary of Relevant NOAEL and LOAEL Values Considered for Derivation of an Acute-Duration Oral MRL for Disulfoton

Species (sex) | Frequency/duration | NOAEL (mg/kg/day ) | LOAEL (mg/kg/day ) | Effect | Reference
Neurological effects
CD rats (F) | GDs 6–15 | 0.1 | 0.3 | 41% inhibition of red blood cell AChE activity in dams | Lamb and Hixson 1983
Holtzman rats (F) | Daily 7 days | 0.05 | 0.25 | 50% inhibition of brain AChE activity | Su et al. 1971
CD rats (M, F) | Once | 0.24 | | Non-significant cholinesterase activity inhibition | Sheets 1993a
Wistar rats (F) | Once | 0.125 | 0.25 | 22% inhibition of red blood cell AChE activity | EPA 2007
Wistar rats (F) | Daily 11 days | 0.125 | 0.25 | 28% inhibition of red blood cell AChE activity and 33% inhibition of brain AChE | Klaus 2006a
Wistar rats (M) | Daily 11 days | 0.25 | 0.5 | 38% inhibition of red blood cell AChE activity and 39% inhibition of brain AChE | Klaus 2006a
Developmental effects
Wistar rats (pups, F) | Daily 11 days | | 0.06 | 29% inhibition of red blood cell AChE activity in pups | Klaus 2006b
Wistar rats (pups, M) | Daily 11 days | 0.06 | 0.125 | 23% inhibition of brain AChE activity in pups | Klaus 2006b
Endocrine effects
Wistar rats (F) | Once | 0.26 | 0.52 | Increased excretion of 4-hydroxy-3-methoxy-mandelic acid in urine (27.8–32%) | Wysocka-Paruszewska 1971

AChE = acetylcholinesterase; F = females; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level

The available data suggest that neurotoxicity, specifically AChE inhibition, is the most sensitive endpoint following acute-duration oral exposure to disulfoton. The lowest LOAEL identified for acute-oral exposure to disulfoton is 0.06 mg/kg/day for 29% inhibition of red blood cell AChE activity in female pups, and inhibition increased with dose (Klaus 2006b). In the same study, the NOAEL for male pups was 0.06 mg/kg/day accompanied by a LOAEL of 0.125 mg/kg/day. These findings are supported by the derived NOAEL of 0.05 mg/kg/day in female rats exposed to disulfoton daily for 7 days (Su et al. 1971). All other NOAELs for neurological effects were >0.1 mg/kg/day. Other effects of disulfoton exposure in acute-duration oral studies include depression of body weight gain (Schwab and Murphy 1981; Pawar and Fawade 1978, 1983), interference with catecholamine levels in body tissues (Brzezinski 1969; Wysocka-Paruszewska 1970, 1971), and lipid peroxidation in the liver (Fawade and Pawar 1978, 1980, 1983). None of these effects occurred at doses lower than the acute-duration oral NOAELs for neurological effects.

Selection of the Principal Study: The Klaus (2006b) study in rat pups was selected as the principal study for deriving an acute-duration oral MRL for disulfoton because it identified the lowest LOAEL of 0.06 mg/kg/day for inhibited red blood cell AChE activity in female pups. A clear dose-response relationship is seen with disulfoton exposure and red blood cell AChE inhibition in female pups (see Table A-5). Female rats were chosen as they were more sensitive to the effects of disulfoton exposure and this higher sensitivity has been seen in several neurotoxicity studies. Male rat pups had a NOAEL of 0.06 mg/kg/day and a higher LOAEL of 0.125 mg/kg/day; therefore, the lower LOAEL in female rats was selected. Su et al. (1971) identified a derived NOAEL of 0.05 mg/kg/day, which is essentially equivalent to the lowest LOAEL; however, the next tested dose of 0.25 mg/kg/day is greater than the lowest LOAEL in Klaus (2006b).

Table A-5 Red Blood Cell and Brain AChE Activity in Male and Female Rat Pups Exposed to Disulfoton Daily via Gavage for 11 Consecutive Days

Dose (mg/kg) | Males (n=10/dose) | | | | Females (n=10/dose)
Dose (mg/kg) | Mean AChE activity (kU/L)± SD | % Inhibition | Mean brain AChE activity (U/g)±SD | % Inhibition | Mean AChE activity (kU/L)±SD | % Inhibition | Mean brain AChE activity (U/g)±SD | % Inhibition
0 (control) | 1.99±0.36 | − | 9.47±0.34 | − | 2.02±0.19 | − | 9.50±0.37 | −
0.06 | 2.14±0.20 | -7.5% | 8.81±0.41 | 7% | 1.44±0.29 | 29% | 8.64±0.24 | 9%
0.125 | 1.61±0.30 | 19% | 7.29±0.46 | 23% | 1.22±0.29 | 40% | 7.22±0.33 | 24%
0.25 | 1.15±0.25 | 42% | 5.58±0.20 | 41% | 0.96±0.21 | 52% | 5.36±0.27 | 44%

AChE = acetylcholinesterase; SD = standard deviation

Source: Klaus 2006b

Summary of the Principal Study:

Klaus AM. 2006b. Data evaluation record: Study type: Non-guideline: Cholinesterase inhibition in rat pups. MRID 46637102. Scientific data reviews: EPA series 361: Subject: 032501: 6(a)(2) data on disulfoton cholinesterase activity after acute dosing in young adults and 11-day old pups at peak time [MRID# 46589701-46589704], in maternal and fetal rats [MRID# 46635901], and in young adults dose 11 days [MRID# 46637101] and 11-day old pups dosed for 11 days [MRID# 46637101]. Washington, DC: U.S. Environmental Protection Agency.

Wistar rat pups were administered 0, 0.06, 0.125, or 0.250 mg/kg/day of disulfoton daily by gavage for 11 consecutive days, beginning on PND 11. Groups contained 10 pups/sex/dose. Pups were observed for clinical signs of toxicity and mortality. Plasma, red blood cell, and brain AChE activity in all rat pups was determined 1 hour after the final dose was administered. Plasma and red blood cell AChE activity were measured in blood following decapitation, and brain AChE was measured by whole-brain analysis.

Four pups (sex unreported) were found dead between PNDs 12 and 18, prior to scheduled sacrifice. However, all pups originated from the same litter and were in different dose groups; therefore, mortality was not likely treatment-related. No clinical signs of toxicity were observed at any dose. In male rat pups, brain and plasma AChE activity decreased with dose. Brain AChE inhibition was significant, with 23–41% inhibition at ≥0.125 mg/kg/day. Red blood cell AChE activity in male pups increased slightly by 7% in the 0.06 mg/kg/day dose group compared to controls, but then decreased dose-dependently by 19% at 0.125 mg/kg/day and 42% at 0.25 mg/kg/day. In female pups, red blood cell and brain AChE decreased dose dependently beginning at the lowest dose. Significant inhibition for red blood cell AChE began at 0.06 mg/kg/day (29% inhibition) and at 0.125 mg/kg/day for brain AChE (24% inhibition). These findings were supported by the dose-related inhibition of plasma AChE. No clinical signs of cholinesterase inhibition were observed in any of the dose groups.

Selection of the Point of Departure for the MRL: The BMDL_20RD_ of 0.028 mg/kg/day for red blood cell AChE activity inhibition in female rat pups was selected as the basis for the oral acute MRL. Red blood cell and brain AChE activity data for male and female rats were fit to all continuous models in EPA’s Benchmark Dose Software (BMDS; version 3.1.2) using a benchmark response (BMR) of 20% relative deviation. The data did not require an adjustment for intermittent exposure. Red blood cell AChE activity data for male rat pups was not selected, as female pups appeared more sensitive to the effects of disulfoton exposure. The data were fit to all available continuous models in EPA’s BMDS (version 3.1.2) using a BMR of 20% relative deviation. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Brain AChE activity data of both sexes did not produce adequate model fit. Using these criteria on red blood cell AChE data, the Exponential 4, Exponential 5, and Hill models provided adequate model fit. Generally, the number of parameters in a model cannot exceed the number of dose groups in the data. For the Hill model specifically, the number of dose groups should exceed the number of parameters by at least one in order to be selected as the POD due to the instability in the model. The Hill model uses five parameters and the Klaus (2006b) study only has four dose levels; therefore, the Hill model was not chosen for the POD. Among the two remaining models providing adequate fit to the data, the Akaike Information Criterion (AIC), BMD, and BMDL values were the same. Therefore, the model with the lower number of parameters (least complex) was selected. Table A-6 presents BMD_20RD_/BMDL_20RD_ values considered for MRL derivation. Therefore the frequentist, restricted Exponential 4 model (Figure A-1) for red blood cell AChE activity in female rat pups was selected for the POD for MRL derivation as it was the least complex.

Table A-6 Results from BMD Analysis of Red Blood Cell AChE Activity in Female Wistar Rat Pups Administered Daily via Gavage for 11 Consecutive Days to Disulfoton

Model | BMD_20RD_^a^ (mg/kg/day) | BMDL_20RD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_20RD_^a^ (mg/kg/day) | BMDL_20RD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2 | 0.069 | 0.057 | 0.026 | 11.42 | -1.68 | 1.29
Exponential 3 | 0.069 | 0.057 | 0.026 | 11.42 | -1.68 | 1.29
Exponential 4 ^d^ | 0.041 | 0.028 | 0.47 | 6.65 | -0.43 | 0.10
Exponential 5 | 0.041 | 0.028 | 0.47 | 6.65 | -0.43 | 0.10
Hill | 0.037 | 0.022 | 0.67 | 6.32 | -0.22 | 0.03
Polynomial Degree 3 | 0.094 | 0.081 | 0.001 | 17.21 | -1.44 | 2.10
Polynomial Degree 2 | 0.094 | 0.081 | 0.001 | 17.21 | -1.44 | 2.10
Power | 0.094 | 0.081 | 0.001 | 17.21 | -1.44 | 2.10
Linear | 0.094 | 0.081 | 0.001 | 17.21 | -1.44 | 2.10

a BMDLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

d Selected model. The Exponential 4, Exponential 5, and Hill models provided adequate fit to the data. The Hill model was excluded as the number of model parameters exceeded the number of dose groups. Among the remaining models, the BMDL for the model with lowest number of parameters was selected (Exponential 4).

AChE = acetylcholine; AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_20RD_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _20RD_ = dose associated with 20% relative deviation)

Figure A-1 Predicted (Frequentist Exponential Degree 4 Model with Constant Variance and 20% Relative Deviation) and Observed Red Blood Cell Acetylcholinesterase Activity in Female Rats

Figure A-1 description

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_20RD_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

M R L = (B M D L_20 R D_)/(U F s) = (0.028 m g / k g / d a y)/(10 × 10) = 0.00028 m g / k g / d a y ( R o u n d e d t o 0.0003 m g / k g / d a y )

Agency Contact (Chemical Managers): Melanie Buser, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.00009 mg/kg/day (0.09 µg/kg/day)
Critical Effect: | Decreased brain AChE activity in offspring
Reference: | Hixson and Hathaway 1986
Point of Departure: | NOAEL of 0.009 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 42
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 0.00009 mg/kg/day (0.09 µg/kg/day) was derived for disulfoton based on decreased brain AChE activity in F1a pups in a multi-generation feeding study in rats (Hixson and Hathaway 1986). The MRL is based on a NOAEL of 0.009 mg/kg/day, which was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Numerous studies have examined the neurological (Christenson and Wahle 1993; Hayes 1985; Klaus 2006c; Sheets 1993b, 2005), developmental (Hixson and Hathaway 1986; Klaus 2006c; Ryan et al. 1970; Sheets 2005; Taylor 1965a), and reproductive (Hixson and Hathaway 1986; Ryan et al. 1970) toxicity of disulfoton following intermediate-duration oral exposure. The LOAELs for studies examining these endpoints range from 0.03 to 21.7 mg/kg/day. Select LOAELs from these studies are presented in Table A-7.

Table A-7 Summary of Relevant Neurological NOAEL and LOAEL Values Considered for Derivation of an Intermediate-Duration Oral MRL for Disulfoton

Species (sex) | Frequency/duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Developmental effects
Sprague-Dawley rats (M, F) | F0: 15 weeks premating; F1b: 13 weeks premating and through pregnancy | 0.009 | 0.03 | 24–32% inhibition of brain AChE activity in F1a pups | Hixson and Hathaway 1986
Wistar rats (NS) | Maternal exposure on GD 0 through 20 | 0.042 | 0.168 | 20% inhibition of red blood cell AChE inhibition in fetal rats | Klaus 2006c
Neurological effects
Fischer 344 rats (F) | Daily for 3–6 months | | 0.06 | 14–22% inhibition of red blood cell AChE | Hayes 1985
Wistar rats (pregnant F) | Continuous on GDs 0–20 | 0.042 | 0.168 | 44% inhibition red blood cell AChE activity and 32% inhibition of brain AChE activity | Klaus 2006c
Fischer 344 rats (F) | 6 months ad libitum | 0.03 | 0.07 | 22–29% inhibition in red blood cell AChE activity | Christenson and Wahle 1993
Reproductive effects
Rats (M, F) | F0: 15 weeks premating; F1b: 13 weeks premating and through pregnancy | 0.009 | 0.03 | Decreased live births in F2b generation, decreased litter weights through gestation | Hixson and Hathaway 1986

AChE = acetylcholinesterase; F = females; LOAEL = lowest-observed-adverse-effect level; M = males; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level

The available data suggest that neurotoxicity, especially AChE inhibition, is the most sensitive endpoint following intermediate-duration oral exposure to disulfoton. Numerous intermediate-duration oral studies in rats, mice, and dogs have found significantly depressed brain or other tissue cholinesterase activities (Clark and Pearson 1973; Hayes 1985; Hoffman and Welscher 1975; Klaus 2006c; Klotzsche 1972; Rivett et al. 1972; Robinson et al. 1978; Ryan et al. 1970; Schwab and Murphy 1981; Sheets 1993b, 2005; Stavinoha et al. 1969; Vaughn et al. 1958). Additionally, signs of cholinergic toxicity were seen in rats including tremors and muscle fasciculations (Hixson and Hathaway 1986; Sheets 1993b) in addition to increased permeability of the central nervous system and increased exploratory behavior (Clark and Stavinoha 1971; Clark et al. 1971). Developmental and reproductive studies in animals reported depression of brain or red blood cell AChE activity in the offspring of rats and reduced litter sizes or failure to produce litters at doses of 0.03–0.5 mg/kg/day (Hixson and Hathaway 1986; Klaus 2006c; Ryan et al. 1970; Taylor 1965a). In addition, cloudy swelling or fatty livers, mild nephropathy, and juvenile hypoplasia of the testes occurred in F3 litters (Taylor 1965a) in fetal rats (Lamb and Hixson 1983). At the lowest LOAEL of 0.03 mg/kg/day, brain AChE activity was inhibited 24–32% in the F1a pups, and litter counts and litter weights were decreased in F2b litters (Hixson and Hathaway 1986). At the SLOAEL of 0.09 mg/kg/day in the same study, effects included tremors in the F0 females during the production of the F1 generation, decreased reproductive performance, decreased maternal F0 and F1 weight during gestation and lactation, decreased litter counts and viability and lactation indices, and increased stillbirth.

Selection of the Principal Study: Both the Hixson and Hathaway (1986) and Klaus (2006c) studies were considered for MRL derivation. Hixson and Hathaway (1986) evaluated developmental neurotoxicity in a multi-generation rat study and observed that mean brain AChE activity of F1 pups was dose-dependent with maternal exposure to disulfoton. This study identified the lowest LOAEL of 0.03 mg/kg/day for brain AChE inhibition, and corresponding NOAEL of 0.009 mg/kg/day. The Klaus (2006c) study also evaluated neurological and developmental toxicity in dams and offspring and demonstrated a dose-response relationship of red blood cell AChE activity and disulfoton exposure. While these data were amenable to dose-response modeling, the resulting BMDL_20RD_ was higher than the lowest LOAEL identified in Hixson and Hathaway (1986); therefore, the latter study was selected for MRL derivation. Mean brain AChE activity of F1a pups from Hixson and Hathaway (1986) is presented in Table A-8.

Table A-8 Mean Brain AChE Activity in F1a Pups in a Multi-Generation Intermediate-Duration Exposure Study

Dose (mg/kg/day) | Male pups (n=10/dose) | | Female pups (n=10/dose)
Dose (mg/kg/day) | Mean±standard deviation (IU/g) | % Inhibition | Mean±standard deviation (IU/g) | % Inhibition
0 (control) | 11.9±0.7 | − | 12.3±0.9 | −
0.009 | 12.0±0.6 | -1 | 12.1±1.2 | 2
0.03 | 9.0±0.6 | 24 | 8.4±1.0 | 32
0.09 | 5.9±1.9 | 50 | 5.0±1.2 | 59

Source: Hixson and Hathaway 1986

Summary of the Principal Study:

Hixson EJ; Hathaway TR. 1986. Effect of disulfoton (Di-syston) on reproduction in rats. Mobay Chemical Corporation, Study Number 82-671-02.

Male and female Sprague-Dawley rats were orally administered disulfoton in feed for 15 weeks at daily doses of either 0, 0.009, 0.03, or 0.09 mg/kg/day; 26 rats/sex/dose all formed the F0 generation. Following the exposure period, 26 female rats and 13 males were mated to produce F1a litters. After 1 month, F0 rats were mated again to produce F1b litters. Pups from the F1b litters were randomly selected, 26 rats/sex/dose except the highest dose where only 22 females were available, and placed into generation F1. F1 rats were given treated feed for 13 weeks at the same doses as F0 rats. They were then mated to produce F2a litters. After 1 month, F1 rats were mated again to produce F2b pups. Toxicological signs were recorded daily and body weight and feed consumption were measured weekly prior to mating. Upon birth, the number of live and stillborn births were recorded. Litter observations (counts, weight, and viability) were recorded at birth and on days 1, 4, 7, 14 and 21. All animals were sacrificed for gross necropsy, and from each generation 10 rats/sex/dose were selected for additional tissue collection for histopathology. One hemisphere of the brain of 10 F1a pups/sex/dose was assayed to measure brain AChE activity.

Signs of AChE inhibition were only seen in F0 adults at the highest dose level, including differences in behavior, appearance, and tremor during gestation and lactation, primarily in dams. F1 rats at the highest dose showed significant decreases in body weights (6–11%) during the pre-mating feeding period and continued through gestation and lactation for F1 dams. At the highest dose level, reproductive performance and litter observations were adversely affected. Effects included decreases in sperm-positive mated F0 and F1 females (an indicator of male reproductive performance), decreased F1 maternal weight during gestation and lactation (including F0 dams), and increased stillbirths. At 0.03 mg/kg/day, F2b litters showed adverse effects including a 25% decrease in live births, and decreased litter weights through the 21-day gestation period. F1a litters did not show similar effects at this level, but upon examination, significantly decreased brain AChE activity (>24% inhibition) was noted in both sexes and was further inhibited in pups at the highest dose (50–59% inhibition).

Selection of the Point of Departure for the MRL: The NOAEL of 0.009 mg/kg/day for brain AChE inhibition in F1a pups in a multi-generation disulfoton exposure study was selected as the basis of the MRL. This NOAEL is also protective against reproductive effects, as demonstrated in Table A-7. These data were fit to all continuous models in EPA’s BMDS (version 3.1.2) using a BMR of 20% relative deviation. For all model tests, the BMDS recommendation was “Questionable,” indicating that none of the models provided an adequate fit for the data. The goodness-of-fit p-values were either <0.1 or the goodness-of-fit test could not be calculated. Therefore, the POD was defined as the NOAEL of 0.009 mg/kg/day.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

M R L = (N O A E L)/(U F s) = (0.009 m g / k g / d a y)/(10 × 10) = 0.00009 m g / k g / d a y

Agency Contact (Chemical Managers): Melanie Buser, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Disulfoton
CAS Numbers: | 298-04-4
Date: | August 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.00006 mg/kg/day (0.06 µg/kg/day)
Critical Effect: | Decreased red blood cell AChE activity
Reference: | Hayes 1985
Point of Departure: | LOAEL of 0.06 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 62
Species: | Rats

MRL Summary: A chronic-duration oral MRL of 0.00006 mg/kg/day (0.06 µg/kg/day) was derived for disulfoton based on red blood cell AChE inhibition in female rats exposed to disulfoton in the diet for 2 years (Hayes 1985). The MRL is based on a LOAEL of 0.06 mg/kg/day, which was divided by a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Disulfoton toxicity from chronic-duration exposure to disulfoton has been examined for various endpoints, most notably for the neurological (Carpy et al. 1975; Hayes 1983, 1985; Hoffman and Welscher 1975; Jones et al. 1999) and ocular (Hayes 1985; Ishikawa and Miyata 1980; Jones et al. 1999) endpoints. The LOAELs for studies range from 0.015 to 2.13 mg/kg/day. Select LOAELs are presented in Table A-9.

Table A-9 Summary of Relevant Neurological NOAEL and LOAEL Values Considered for Derivation of a Chronic-Duration Oral MRL for Disulfoton

Species (sex) | Frequency/duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological
F-344 rats (M) | Daily 104–106 weeks | 0.05 | 0.18 | Depressed red blood cell and brain AChE, optic nerve degeneration | Hayes 1985
F-344 rats (F) | Daily 104–106 weeks | | 0.06 | 24% inhibition of red blood cell AChE after 53 weeks of exposure | Hayes 1985
Sprague-Dawley rats (M) | Daily 1.5–2 years | 0.05 | 0.06 | 26–37% inhibition of brain AChE | Carpy et al. 1975
Sprague-Dawley rats (F) | Daily 1.5–2 years | 0.09 | 0.1 | 21% inhibition of brain AChE | Carpy et al. 1975
Beagle dogs (F) | Daily 12 months | 0.013 | 0.09 | 22% inhibition of brain AChE | Jones et al. 1999
Beagle dogs (M, F) | Daily 2 years | 0.03 | 0.14 | 46–53% inhibition of red blood cell AChE; 34.4% inhibition of brain AChE in males | Hoffman and Welscher 1975
Ocular
Beagle dogs (M) | Daily 12 months | | 0.015 | 33% inhibition of cornea cholinesterase | Jones et al. 1999
F-344 rats (F) | Daily 104–106 weeks | 0.06 | 0.21 | cystic degeneration of Harderian gland | Hayes 1985

AChE = acetylcholinesterase; F = female; LOAEL = lowest-observed-adverse-effect level; M = male; NOAEL = no-observed-adverse-effect level

Brain and red blood cell AChE inhibition appears to be the primary critical effect following chronic-duration oral exposure to disulfoton. As presented in Table A-9, inhibition of brain and red blood cell AChE was found in rats given 0.06 mg/kg/day, but not in rats given 0.05 mg/kg/day, of disulfoton in the diet for 1.5–2 years (Carpy et al. 1975; Hayes 1985). The same effect was seen in mice given 2.13 mg/kg/day (males) and 2.53 mg/kg/day (females), but not 0.5 mg/kg/day, disulfoton for 23 months (Hayes 1983). In a 1-year feeding study in dogs given 0.09 mg/kg/day, brain AChE was inhibited by 22% but no significant inhibition was noted at 0.013 mg/kg/day (Jones et al. 1999). This is consistent with another 1-year feeding study in dogs where red blood cell and plasma AChE activities were significantly inhibited at a time-weighted-average dose of 0.14 mg/kg/day, but not at 0.03 mg/kg/day (Hoffman and Welscher 1975).

Ocular effects (degeneration of ciliary muscles cells, myopia, and astigmatism) were seen in dogs at 0.63 mg/kg/day (Ishikawa and Miyata 1980), cystic degeneration of the Harderian gland at 0.21 mg/kg/day, and corneal neovascularization at 0.75 mg/kg/day in rats (Hayes 1985). No ocular effects were seen at 0.06 mg/kg/day (Hayes 1985). However, female dogs treated with 0.015 mg/kg/day in the diet for 1 year had a 33% decrease of corneal cholinesterase activity, but no effects were seen in male dogs given 0.013 mg/kg/day (Jones et al. 1999). Dogs treated with 0.5 mg/kg/day disulfoton in capsules (Uga et al. 1977) and rats given 0.18 mg/kg/day in the diet (Hayes 1985) for 2 years had optic nerve degeneration. In addition, rats given disulfoton in the diet for 2 years had granulomatous and suppurative inflammation of the lungs, pancreatic atrophy, dermal lesions, decreased body weight gain, and plasma cell hyperplasia in the mandibular lymph nodes at 0.75 mg/kg/day, and mucosal hyperplasia and chronic inflammation of the forestomach, and splenic lymphoid follicle depletion at 1.02 mg/kg/day.

Selection of the Principal Study: Although NOAEL values of 0.03 mg/kg/day (Hoffman and Welscher 1975) and 0.01 mg/kg/day (Jones et al. 1999) were found in dogs, the associated LOAELs, 0.14 and 0.09 mg/kg/day, respectively, are higher than the lowest LOAEL of 0.06 mg/kg/day for neurological effects in rats (Carpy et al. 1975; Hayes 1985). While Carpy et al. (1975) found a NOAEL and corresponding LOAEL for brain AChE inhibition, the study reported high mortality among controls, as mortality was higher in control females than in any of the female exposure groups. Additionally, the dose for the lowest exposure group, 0.5 ppm was changed to 5 ppm after 80 weeks to purposefully produce an adverse effect. In Hayes (1985), a NOAEL of 0.05 mg/kg/day was found for male rats, which is similar to the LOAEL of 0.06 mg/kg/day for female rats in the same study. Use of the LOAEL, instead of the NOAEL, results in a more protective MRL given the lower dose at which the effects were observed. Since neurological effects are a critical endpoint for disulfoton in both animals and humans, the Agency opted to select the study that would result in the most health-protective MRL, which is Hayes (1985). Table A-10 presents the dose-response relationship of red blood cell AChE activity and disulfoton in female rats over 53, 79, and 105 weeks, in Hayes (1985). Hayes (1985) was selected as the principal study for the development of a chronic-duration oral MRL.

Table A-10 Red Blood Cell AChE Activity in Female Rats in an Oral Chronic-Duration Study

Dose (mg/kg/day) | 53 weeks (n=60) | | 79 weeks (n=60) | | 105 weeks (n=60)
Dose (mg/kg/day) | Mean activity (IU/ml) | Inhibition (%) | Mean activity (IU/ml) | Inhibition (%) | Mean activity (IU/ml) | Inhibition (%)
0 (control) | 1.55 | − | 1.50 | − | 1.48 | −
0.06 | 1.18 | 23.9 | 1.21 | 19.3 | 1.31 | 11.5
0.21 | 0.44 | 71.6 | 0.35 | 76.6 | 0.63 | 57.4
1.02 | 0.31 | 80.0 | 0.27 | 82.0 | 0.36 | 75.7

Source: Hayes 1985

Summary of the Principal Study:

Hayes RH 1985. Chronic feeding/oncogenicity study of technical disulfoton (Di-Syston) with rats. Mobay Chemical Corporation, Study Number 82-271-01.

Male and female Fischer-344 rats were fed disulfoton in the diet for 2 years at nominal concentrations of 0, 1, 4, or 16 ppm with 60 rats/sex/dietary level, resulting in mean concentrations of 0, 0.87, 3.6, and 14 ppm, respectively. Using gas chromatographic analysis, mean effective dose concentrations of 0.8, 3.3, and 13 ppm were calculated. Based on body weight and food consumption data supplied by the study investigators, these concentrations were equivalent to doses of 0.05, 0.18, and 0.75 mg/kg/day in males and 0.06, 0.21, and 1.02 mg/kg/day in females. Rats were observed for toxic effects, tumors, mortality, feed consumption, body weight, blood chemistry, hematology, urinalysis, organ weight, gross necropsy, and histopathology. Plasma and red blood cell AChE activities were analyzed at study initiation, and at months 3, 6, 12, 18, and 24 of the study. Brain AChE was analyzed from blood at the orbital plexus at study termination.

At the highest dose for females, a high mortality of 40% was observed. At the same dose level in females, effects among multiple endpoints were observed including acanthosis, hyperkeratosis, ulcer of the skin, chronic inflammation of the forestomach, and mucosal hyperplasia. Additionally, an 11–19% decrease in body weight, splenic lymphoid follicle depletion, skeletal muscle atrophy, corneal neovascularization, uterine cystic hyperplasia, and lung inflammation were seen at 1.02 mg/kg/day. Similar effects were observed in male rats at the highest dose level of 0.75 mg/kg/day, including decreases in body weight, skin ulceration, and corneal neovascularization, in addition to pancreatic atrophy, plasma cell hyperplasia in the mandibular lymph nodes, and eye inflammation. Depressed brain and red blood cell AChE activities were the most sensitive endpoint observed in the study. At 0.06 mg/kg/day, red blood cell AChE activity was inhibited by 24%, and at 0.18 mg/kg/day red blood cell and brain AChE activities were inhibited by 46–67% and 53%, respectively, in addition to optic nerve degeneration. These effects were also seen at higher doses in both sexes.

Selection of the Point of Departure for the MRL: The LOAEL of 0.06 mg/kg/day for red blood cell AChE inhibition in females rats chronically exposed to disulfoton for 53 weeks was selected as the basis of the MRL. At 79 weeks, red blood cell AChE inhibition at 0.06 mg/kg/day was 19.3%, and is biologically similar to the technical threshold of significant inhibition (20%), to support the LOAEL seen at 53 weeks. Additionally, a similar dose-response relationship was observed at weeks 53 and 79 in males. Red blood cell AChE inhibition at 105 weeks was not significant at 0.06 mg/kg/day; however, the study reported unusually low mortality rates among female controls by week 104, and high-dose females had high mortality by week 105. No AChE inhibition was seen in male rats exposed to the same nominal concentration of disulfoton, but the analytical concentration was 0.05 mg/kg/day. The available data in Hayes (1985) are not amenable to BMD modeling as neither standard deviation nor standard error values were provided for AChE levels presented in Table A-10.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL is divided by a total uncertainty factor of 1,000:

- 10 for extrapolation from animals to humans
- 10 for human variability
- 10 for use of a LOAEL

M R L = (L O A E L)/(U F s) = (0.06 m g / k g / d a y)/(10 × 10 × 10) = 0.00006 m g / k g / d a y

Other Additional Studies of Pertinent Information that Lend Support to this MRL: The EPA Integrated Risk Information System (IRIS) Assessment (IRIS 2002) used the same study to calculate an oral reference dose (RfD) of 4x10^-5^ mg/kg/day. This oral RfD was based on a LOAEL of 0.04 mg/kg/day for cholinesterase inhibition and optic nerve degeneration. This value is different from the value used in this chronic-duration oral MRL, as the LOAEL used by EPA was calculated by multiplying the analytical dietary concentration of 0.8 ppm by the reference rat food consumption of 0.05 mg/kg/day. The LOAEL of 0.06 mg/kg/day used to derive the MRL was calculated using the body weight and food consumption data provided in Hayes (1985). In 2004, EPA announced that the IRIS program would no longer evaluate or update pesticide chemicals but that these chemicals would instead be evaluated by EPA’s Office of Pesticide Programs (OPP) (EPA 2004). In 2006, EPA’s OPP evaluated the data on disulfoton. In EPA’s Reregistration Eligibility Decision for disulfoton, a chronic dietary population adjusted dose (PAD) of 0.00013 mg/kg/day using the NOAEL of 0.013 mg/kg/day from the Jones et al. (1999) study in dogs was developed. The chronic-duration oral MRL for disulfoton developed by ATSDR is more protective than EPA’s chronic dietary PAD.

Agency Contact (Chemical Managers): Melanie Buser, MPH