# CHAPTER 8 REFERENCES

ACGIH. 2019. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. CAS number index. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. 263–282.
Ahuja S, Thompson G, Smith J. 1989. Trace/ultratrace analyses of unstable compounds: Investigations on hydrazobenzene and azobenzene. J Chromatogr 471:443–446. 10.1016/s0021-9673(00)94192-x.
Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19(9):799–828. 10.1002/kin.550190903.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://www.govinfo.gov/app/details/FR-1989-09-11. May 11, 2020.
ATSDR. 2019. 1,2-Diphenylhydrazine. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bolton GC, Griffiths LA. 1978. Metabolism of hydrazines and hydrazides by the intestinal microflora. Experientia 34(11):1484–1486. 10.1007/BF01932368.720479
Camanzo J, Rice CP, Jude DJ, . 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments, 1983. J Great Lakes Res 13(3):296–309. 10.1016/S0380-1330(87)71653-0.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
De Vault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14(5):587–594. 10.1007/bf01055389.
Dean J. 1985. 1,2-Diphenylhydrazine. In: Lange’s handbook of chemistry. 13th ed. New York, NY: McGraw-Hill Book Co., 7–368.
Dietrich MJ, Randall TL, Canney PJ. 1985. Wet air oxidation of hazardous organics in wastewater. Environ Prog 4(3):171–177. 10.1002/ep.670040312.
Dodd DE, Pluta LJ, Sochaski MA, . 2012. Subchronic hepatotoxicity evaluation of hydrazobenzene in Fischer 344 rats. Int J Toxicol 31(6):564–571. 10.1177/1091581812465322.23134713
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Dunkel VC, Zeiger E, Brusick D, . 1985. Reproducibility of microbial mutagenicity assays: II. Testing of carcinogens and noncarcinogens in Salmonella typhimurium and Escherichia coli. Environ Mutagen 7(Suppl 5):1–248. 10.1002/em.2860070902.
Dutkiewicz T, Szymanska J. 1973. [Chromatographic determination of hydrazobenzene metabolites in rats]. Bromatol Chem Toksykol 6:323–327. (Polish)
EPA. 1981. Comparison of Grob closed-loop stripping analysis (CLSA) with other trace organic methods. U.S. Environmental Protection Agency. EPA600D81060. PB81211450. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91020OUQ.txt. May 12, 2020.
EPA. 1982a. Aquatic fate process data for organic priority pollutants. Final report. Washington, DC: U.S. Environmental Protection Agency. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. May 12, 2020.
EPA. 1982b. Determination of benzidines in industrial and municipal wastewaters. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S482022. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TT4Y.txt. May 12, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://19january2017snapshot.epa.gov/sites/production/files/documents/ry2004rfi.pdf. May 11, 2020.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute exposure guideline levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
Fabre H, Hussam-Eddine N, Mandrou B. 1984. Stability-indicating assay for phenylbutazone: high-performance liquid chromatographic determination of hydrazobenzene and azobenzene in degraded aqueous phenylbutazone solutions. J Pharm Sci 73(12):1706–1709. 10.1002/jps.2600731211.6527240
FDA. 2009. Determination that Thorazine (chlorpromazine hydrochloride) injection and 18 other drug products were not withdrawn from sale for reasons of safety or effectiveness. U.S. Food and Drug Administration. Fed Regist 74(113):28255–29256. https://www.govinfo.gov/content/pkg/FR-2009-06-15/html/E9-13988.htm. May 11, 2020.
FDA. 2016. Product safety information. Phenylbutazone in horses- veterinarians. U.S. Food and Drug Administration. https://www.fda.gov/animalveterinary/safetyhealth/productsafetyinformation/ucm186621.htm. June 12, 2017.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Ferber KH. 1978. Benzidine and related biphenyldiamines. In: Encyclopedia of chemical technology. Vol. 3. 3rd ed. New York, NY: McGraw-Hill Book Co., 772–777.
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: evaluations of 108 chemicals. Environ Mol Mutagen 10(Suppl 10):1–175. 10.1002/em.2850100502.3319609
Genin VA, Medvedovskii AG, Voronin VM. 1975. [Potentiation of the carcinogenic activity in the joint action of hydrazobenzene and benzidine sulfate]. Gig Tr Prof Zabol (6):28–31. (Russian)
Hall LW, Pinkney AE, Horseman LO, . 1985. Mortality of striped bass larvae in relation to contaminants and water quality in a Chesapeake Bay tributary. Trans Amer Fish Soc 114(6):861–868. 10.1577/1548-8659(1985)114<861:mosbli>2.0.co;2.
Hansch C, Leo A, Hoekman D. 1995. 1,2-Diphenylhydrazine. In: Exploring QSAR - hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 99.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):1–142. 10.1002/em.2860050703.
Hughes DW. 1981. Malonic acid and derivatives. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 14. 3rd ed. New York, NY: Wiley-Interscience, 794, 803–810.
IARC. 1972. Benzidine. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to man. Geneva, Switzerland: International Agency for Research on Cancer. Vol. 1, 80–86. https://publications.iarc.fr/19. May 12, 2020.
IARC. 2020. Agents classified by the IARC Monographs, Volumes 1–125. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. April 30, 2020.
IRIS. 2006. 1,2-Diphenylhydrazine; CASRN 122-66-7. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0049_summary.pdf. May 10, 2017.
Kitchin KT, Brown JL, Kulkarni AP. 1992. Predictive assay for rodent carcinogenicity using in vivo biochemical parameters: operational characteristics and complementarity. Mutat Res 266(2):253–272. 10.1016/0027-5107(92)90193-6.1373835
Kitchin KT, Brown JL, Kulkarni AP. 1994. Complementarity of genotoxic and nongenotoxic predictors of rodent carcinogenicity. Teratog Carcinog Mutagen 14(2):83–100. 10.1002/tcm.1770140205.8066550
Kornis G. 1982. Pyrazoles, pyrazolines, pyrazolones. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 19. 3rd ed. New York, NY: McGraw-Hill Book Co., 448–451.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kurliandskii BA, Medvedovskii AG, Genin VA, . 1976. [Experimental study of the combined action of some diphenyl amino derivatives for the purpose of preventing occupational neoplasms of the bladder]. Gig Tr Prof Zabol (5):34–38. (Russian)
Lurie AP. 1964. Benzidine and related diaminobiphenyls. In: Encyclopedia of chemical technology. Vol. 3. 2nd ed. New York, NY: McGraw-Hill Book Co., 408, 413, 420.
Lyman WJ, Reel WF, Rosenblatt DH. 1982. Environmental behavior of organic compounds. In: Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 4–8; 15–16.
Macholz R, Kujawa M, Schulze J, . 1985. The metabolism of some xenobiotics in germ-free and conventional rats. Arch Toxicol Suppl 8:373–376. 10.1007/978-3-642-69928-3_77.
Marhold J, Matrka M, Hub M, . 1968. The possible complicity of diphenyline in the origin of tumours in the manufacture of benzidine. Neoplasma 15(1):3–10.5650629
Maronpot RR, Montgomery CA, Boorman GA, . 1986a. National Toxicology Program nomenclature for hepatoproliferative lesions of rats. Toxicol Pathol 14(2):263–273. 10.1177/019262338601400217.3764323
Maronpot RR, Shimkin MB, Witschi HP, . 1986b. Strain A mouse pulmonary tumor test results for chemicals previously tested in the National Cancer Institute carcinogenicity tests. J Natl Cancer Inst 76(6):1101–1112. 10.1093/jnci/76.6.1101.3458947
Matsui F, Lovering EG, Curran NM, . 1983. Determination of azobenzene and hydrazobenzene in phenylbutazone and sulfinpyrazone products by high-performance liquid chromatography. J Pharm Sci 72(10):1223–1224. 10.1002/jps.2600721032.6644580
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35. https://www.nap.edu/catalog/774/biologic-markers-in-reproductive-toxicology. May 11, 2020.
NCI. 1978. Bioassay of hydrazobenzene for possible carcinogenicity. Washington, DC: National Cancer Institute. TR-92. Publication No. (NIH) 78-1342. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr092.pdf. May 11, 2020.
NIOSH. 2018. NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 2, 2019.
NLM. 2020. PubChem compound summary: 1,2-diphenylhydrazine. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/31222. May 14, 2020.
NRC. 1981. Metabolism of aromatic amines. Aromatic amines: An assessment of the biological and environmental effects. Washington, DC: National Research Council. PB83133058. 10.17226/664.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments- February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. April 13, 2016.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. October 2, 2015.
NTP. 2016. Hydrazobenzene, CAS No. 122-66-7. Report on carcinogens, fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/hydrazobenzene.pdf. June 6, 2017.
NWQMC. 2020. 1,2-Diphenylhydrazine sample results. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=1%2C2-Diphenylhydrazine&mimeType=csv. May 11, 2020.
Ohnishi S, Murata M, Oikawa S, . 2000. Copper-dependent DNA damage induced by hydrazobenzene, an azobenzene metabolite. Free Radic Res 32(6):469–478. 10.1080/10715760000300471.10798712
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Patterson JW, Kodukala PS. 1981. Biodegradation of hazardous organic pollutants. Chem Eng Prog 77(4):48–55.
Pfordte K. 1973. [Acute toxicity and hemiglobine-forming properties of various industrial noxes. Nitrobenzole and its reduction products]. Z Gesamte Hyg 19(1):35–39. (German)4700986
Pliss GB. 1974. [Carcinogenic properties of hydrazobenzene]. Vopr Onkol 20(4):53–57. (Russian)
RePORTER. 2020. 1,2-Diphenylhydrazine. Research Portfolio Online Reporting Tools. National Institutes of Health. http://projectreporter.nih.gov/reporter.cfm. April 30, 2020.
Riggin RM, Howard CC. 1979. Determination of benzidine, dichlorobenzidine, and diphenylhydrazine in aqueous media by high performance liquid chromatography. Anal Chem 51(2):210–214. 10.1021/ac50038a014.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Sandridge RL, Staley HB. 1978. Amines by reduction. In: Encyclopedia of chemical technology. Vol. 2. 3rd ed. New York, NY: McGraw-Hill Book Co., 355–376.
Schafer EW, Bowles WA. 1985. Acute oral toxicity and repellency of 933 chemicals to house and deer mice. Arch Environ Contam Toxicol 14(1):111–129. 10.1007/bf01055769.3977403
Seiler JP. 1977. Inhibition of testicular DNA synthesis by chemical mutagens and carcinogens. Preliminary results in the validation of a novel short term test. Mutat Res 46(4):305–310. 10.1016/0165-1161(77)90007-3.895760
Shabad LM, Genin VA. 1975. [Combined action of aminoderivatives of diphenyl, substances inducing neoplasms of the urinary bladder]. Urol Nefrol (Mosk) 1(1):38–42. (Russian)
Spitz S, Maguigan WH, Dobriner K. 1950. The carcinogenic action of benzidine. Cancer 3(5):789–804. 10.1002/1097-0142(1950)3:5<789::aid-cncr2820030505>3.0.co;2-u.14772711
Tabak HH, Quave SA, Mashni CI. 1981a. Biodegradability studies for predicting the environmental fate of organic priority pollutants. In: Test protocols for environmental fate & movement of toxicants : Proceedings of a symposium, Association of Official Analytical Chemists, 94th annual meeting, October 21, 22, 1980, Washington, DC. Arlington, VA: AOAC, 267–328.
Tabak HH, Quave SA, Mashni CI, . 1981b. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Tang IS, Yen TF, Kawahara FK. 1983. Separation and identification of the organic species in coal conversion process wastewater. In: Yen TF, Kawahara FK, Hertzberg R, eds. Chemical and geochemical aspects of fossil energy extraction. Ann Arbor, MI: Ann Arbor Science Publishers, 85–106.
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. February 10, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Williams RT. 1959. The metabolism of dyestuffs and other colouring matters. In: Detoxication mechanisms. The metabolism and detoxication of drugs, toxic substances and other organic compounds. 2nd ed. New York, NY: John Wiley and Sons, Inc., 472–488.
Yoon JS, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in Drosophila. IV. Results of 45 coded compounds tested for the National Toxicology Program. Environ Mutagen 7(3):349–367. 10.1002/em.2860070310.3930235