# VERSION HISTORY

Date | Description
October 2020 | Final toxicological profile released
May 2019 | Draft for public comment toxicological profile released
October 2009 | Toxicological profile addendum
December 1990 | Final toxicological profile released